# Health Communication

Definition

The study or use of communication strategies to inform and influence individual and community decisions that affect health (adapted from Healthy People 2020 (http://www.healthypeople.gov/2020/default.aspx)).

Discussion

This field encompasses many areas of research and practice, such as health risk communication, health literacy, mass communication of health and medicine, patient-professional communication, and the development of telemedicine applications.

Scope and emphasis

Collected comprehensively.

## See also

Medical Informatics

Public Health