# Gynecology

Definition

The study of the physiology and disorders of the female genital tract and related reproductive physiology and endocrinology (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D006176)).

Scope and emphasis

Collected comprehensively.