# Geriatrics

Definition

The branch of medicine concerned with the health of the aged and the process of aging.

Discussion

The closely related field of gerontology is the study of the biological, psychological, sociological, health, and economic aspects of aging.

Scope and emphasis

NLM comprehensively collects geriatrics, and the biological, psychological and health aspects of gerontology.

## See also

Medical Sociology