# Gastroenterology

Definition

The branch of medicine concerned with the physiology and diseases of the digestive system and related structures.

Scope and emphasis

Collected comprehensively.