# Forensic Medicine

Definition

The application of medical knowledge to questions of law (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D005554)).

Discussion

Forensic medicine encompasses several specialties, such as forensic pathology, odontology, and psychiatry. A major focus is medicolegal death investigation, but medical forensic specialists also work in areas such as malpractice, investigation of human rights violations, and litigation related to occupational and environmental health issues.

Scope and emphasis

Collected comprehensively.