# Family Practice

Definition

The branch of medicine concerned with the provision of continuing, comprehensive primary health care for the entire family.

Scope and emphasis

Collected comprehensively.