# Fact Sheets

Fact sheets provide health information in an economical, easily distributed form. NLM may collect compilations of fact sheets issued by influential agencies or societies, or of potential interest to historians. The Library generally does not collect individual fact sheets for the General Collection.

## See also

Ephemera

Pamphlets