# Examination Review Guides

This category includes publications that assist students preparing for entrance, board certification, recertification, or licensing examinations.

Examination review guides provide information concerning generally recognized standards, requirements and prerequisites for formal education and licensure in the health professions, and thus may be valuable for historical research as well as current use. However, since this category is characterized by a high volume of publishing and many competing, redundant titles, the Library does not maintain a comprehensive collection. NLM selectively collects examples of guides to U.S. examinations, with emphasis on widely disseminated titles that have substantive content and that are produced by major U.S. medical publishers or recognized professional organizations. The Library also collects guides for disciplines for which the majority of publishing is in this format (e.g., allied health professions). NLM does not collect foreign examination review guides or guides that assist students to prepare for examinations based upon specific textbooks.

## See also

Continuing Education Publications

Textbooks