# Endocrinology

Definition

The branch of medicine and science concerned with the physiology and disorders of the endocrine system.

Discussion

NLM comprehensively collects basic endocrinological research in any species, as well as clinical studies in all areas of endocrinology and metabolism.

Scope and emphasis

Collected comprehensively.