# Emergency Medicine

Definition

The branch of medicine concerned with the provision of immediate treatment to the acutely ill or injured.

Scope and emphasis

Collected comprehensively.

Special considerations

NLM collects examples of literature (handbooks, guides, etc.) written for first responders.

First aid materials intended for the public are collected very selectively, with emphasis on authoritative U.S. or international manuals.

## See also

Disaster Management