# Embryology

Definition

The science dealing with the formation, development, structure and functional activity of the embryo.

Scope and emphasis

The NLM collecting emphasis is on human and comparative embryology.

## See also

Biological Sciences