# Education for the Health Professions

Definition

Education and training of physicians, nurses, and other health practitioners.

Discussion

This field includes practical and theoretical inquiries into all aspects of education and training for the health professions. Typical areas of research include quality of education; innovations in teaching; academic leadership; curricular matters; diversity and other recruitment and admissions policies; economics of education for the health professions; role of teaching hospitals in public health; student and resident issues; integration of teaching, research, and health care practice; and the future of academic medicine.

Scope and emphasis

Collected comprehensively.

## See also

Biomedical Research

Health Occupations

Medical Sociology