# Drafts

A draft is a preliminary version of a written work, often written for comment, approval, or clearance by others. NLM selectively collects drafts of scientific articles that are either posted publicly to a preprint server prior to peer review or that have undergone peer review and been accepted for publication in a journal. A primary selection criterion is drafts developed with National Institutes of Health (NIH) support, maximizing the impact of the research. NLM makes such drafts discoverable via PubMed Central (https://www.ncbi.nlm.nih.gov/pmc/) and PubMed (https://pubmed.ncbi.nlm.nih.gov/).

## See also

Journals