# Dermatology

Definition

The study of the skin, its structure, functions, diseases, and treatment (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D003880)).

Scope and emphasis

Collected comprehensively.

Special considerations

Since the visual aspect is so important in dermatology, audiovisual media are especially valuable in this area of medicine.

## See also

Audiovisual Materials