# Dentistry

Definition

The branch of medicine concerned with the teeth, oral cavity, and associated structures, and the diagnosis and treatment of their diseases including prevention and the restoration of defective and missing tissue (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D003813)).

Scope and emphasis

Collected comprehensively.