# Continuing Education Publications

Continuing education materials provide evidence of the content, instructional techniques and educational philosophies found in formal education for the health professions. These materials typically contain information collected from other sources and reorganized into forms suitable for instructional purposes. NLM collects this category very selectively, primarily for historical purposes. Continuing education materials that describe new concepts, demonstrate new techniques, or document contemporary concerns of the U.S. health professional are of particular collecting interest.

## See also

Examination Review Guides

Textbooks