# Communication Disorders

Definition

Disorders of verbal and nonverbal communication caused by receptive or expressive language disorders, hearing disorders, cognitive dysfunction, or other neurological or psychiatric conditions.

Scope and emphasis

The NLM collecting emphasis is on works on the anatomical, physiological and cognitive basis of communication and the diagnosis and treatment of communication disorders. The Library does not collect works on sign language, language education, or the social, political, or cultural aspects of deafness.

## See also

Physical Medicine and Rehabilitation