# Collection Overview

As one of five national libraries in the United States and one of the twenty-seven institutes and centers of the National Institutes of Health, the National Library of Medicine (NLM) is the world's largest and most comprehensive biomedical library, with a rich collection spanning ten centuries, originating from nearly every part of the globe and in virtually every written language. The Library collects materials of all formats—physical and digital—in all areas of biomedicine, health care and the history of medicine as well as works on biomedical aspects of the humanities, physical, social and life sciences.

The Library's collection is constantly growing and encompasses tens of millions of items, ranging from ancient manuscripts to born digital publications and datasets.

The Library's acquisitions program is international in scope, including arrangements with book dealers, subscription agents, media producers, publishers, governments, societies, and libraries worldwide. NLM also receives donations from around the world.

Much of the Library's collection can be accessed online. Materials may also be consulted in its on-site reading room or requested via interlibrary loan.

## A Collection of Distinction

The NLM holds a rich collection of literature and data, as well as printed, hand-written, and visual archival materials spanning the centuries and reflecting the diversity of philosophical and cultural perspectives on medicine. Acquired by generations of professionals since the Library was formally established in 1836, the collection today aligns with the many scientific focus areas of the NIH (https://irp.nih.gov/our-research/scientific-focus-areas) and illuminates subjects of concern in 21^st^ century science and society, including medical misinformation, informed consent and patient rights, the relationship between the environment and public health, and the promises and challenges of new technology.

The NLM collection is not merely the largest of its kind in the world, but also one of the most distinctive for its depth and breadth of genomic information, medical terminologies, clinical studies, and literature. The Library holds landmark works in medicine as well as countless lesser-known works which document medical knowledge across time and around the world. Notable unique, rare, and expansive holdings include:

- early manuscripts (pre-1600), modern manuscripts (17^th^ century to the present), as well as pamphlets and dissertations of multiple centuries and languages.
- personal and professional papers of hundreds of American medical practitioners, biomedical scientists, public health practitioners and researchers, and health policy planners, including those of Nobel Prize-winning scientists and leaders of the NIH. The Library’s oral history collection consists of about 200 memoirs of important figures in the health sciences. The collection comprises audiotapes, videotapes, and unpublished or restricted transcripts of potential value to scholars.
- terabytes of born digital internet content, much of which is ephemeral given the character of the web, including collections documenting the H7N9 Avian Flu, autism and Alzheimer’s disease, and global health events, including the 2014 Ebola Outbreak and COVID-19 pandemic.
- new forms of publication on the web, such as blogs authored by doctors and patients, illuminating health care thought and practice in the 21st century.
- reprints of more than 1,300 important Chinese medical works dating from before the Han dynasty (202 BC – 9 AD, 25–220 AD) and 139 Arabic and Persian medical manuscripts, including a manuscript on gastrointestinal diseases from al-Razi's The Comprehensive Book on Medicine (Kitab al-Hawi fi al-tibb) dated 1094.
- internal records of NLM and its official publications, including the papers of John Shaw Billings and other Library Directors, Board of Regents meeting minutes, annual reports, selected administrative records from the Library's operational divisions, archival copies of NLM publications and some oral histories, and electronic copies of NLM web site documents and files that are no longer current but are considered to be of permanent value. Note: Most internal records of the National Institutes of Health (https://www.nih.gov/) are in the National Archives and Records Administration (https://www.archives.gov/).
- prints and photographs, numbering in the hundreds of thousands, illustrating social and historical aspects of medicine. Such holdings encompass 15th century woodcuts, 19^th^ and 20^th^ century fine prints, photographs, portraits, public health posters, and visual ephemera such as patent medicine trade cards, and 21st century born digital images.
- audiovisuals, numbering in the hundreds of thousands, including films, videocassettes, slide-tape programs, film strips, and audiocassettes produced between 1917 and 1970, all which also illustrate social and historical aspects of medicine.