# Collected Works

NLM selects collected works when the original works are not in the collection, when the compilation contains additional information or commentary, or when presentation of the material as a unit is of value for scholarship.

## See also

Reprints and Facsimiles