# Cognitive Science

Definition

The study of the functional processes of the mind, and the operations of the brain that enable these processes to be performed.

Discussion

Cognitive science combines the research of cognitive psychology and the neurosciences with research in computer science, artificial intelligence, philosophy, mathematical logic and linguistics to study knowledge representation, memory, language, learning, thinking, and perception.

Scope and emphasis

NLM comprehensively collects in all areas of cognitive science research, including, for example, computer modeling of cognition and of neurological systems; the development of biological-computer interfaces; and psycholinguistics (the study of language acquisition, development, production and processing in the individual).

## See also

Neuroscience

Psychology