# Clinical Laboratory Science

Definition

The use of laboratory techniques in diagnosis, patient monitoring and therapeutic problem-solving. It involves the selection, performance and interpretation of laboratory tests for patient care, and the testing and analysis of pharmaceuticals used in medical treatment.

Scope and emphasis

Collected comprehensively.