# Cell Biology

Definition

Cell biology is the study of the structure and function of the basic unit of living organisms, the cell.

Discussion

Cell biology includes the study of the cell life cycle (including cell death and cancer), cell differentiation (including stem cell research), cell motility and behavior, and organelles and other cellular structures in the growth and functioning of the cell (including membrane transport and signaling).

Scope and emphasis

NLM comprehensively collects cell biology resources.

## See also

Cytology

Microbiology

Plant Biology