# Cardiology

Definition

The study of the heart, its physiology, functions and the diseases that affect it (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D002309)).

Scope and emphasis

Collected comprehensively.