# Biotechnology

Definition

Biotechnology is the body of knowledge related to the use of organisms, cells or cell-derived constituents for the purpose of developing products which are technically, scientifically and clinically useful.

Discussion

Biotechnology is an interdisciplinary subject that spans medicine, agriculture, industrial technology and commerce, and impacts health, culture, and society. The literature of biotechnology is derived from diverse fields and includes basic research publications in molecular and cellular biology, as well as materials describing basic biological processes from several disciplines: biochemistry, genetics, immunology, virology, microbiology and protein structural analysis. The literature of biotechnology also embraces the fields of medical practice and medical ethics.

Scope and emphasis

NLM comprehensively collects works in biotechnology including materials dealing with the alteration of biologic function by changing genetic information, i.e., genetic engineering. NLM is also interested in biotechnology laboratory tools and methods, which include transfection, cloning technologies, molecular sequence and structure/function analysis prediction algorithms, and databases. NLM collects the history of biotechnology as it relates to the history of human medicine, and contemporary implications of biotechnology for medical practice and medical ethics.

Centrally important are publications about genes, proteins, and cells and tissues, when related to humans, primates, or model organisms and with a potential for application to human health care and disease prevention. NLM also collects, but not as broadly, other animal studies of these topics, the use of organisms in sanitary engineering, and the environmental effects of biotechnology on humans or animals.

## See also

Biochemistry

Bioengineering

Bioethics

Genetics