# Biomedical Research

Definition

Research that is conducted to increase fundamental knowledge and understanding of the physical, chemical and functional mechanisms of human life processes and diseases.

Scope and emphasis

NLM comprehensively collects works on the organization, management, and funding of biomedical research; on research design, tools, methods and models as applied to biomedical research, including analytical, statistical and computational techniques; on research ethics and scientific fraud; and on the interrelationship between the biomedical research community and government or other organizations concerned with research outcomes and public policy.

## See also

Bioethics

Health Policy

Laboratory Animal Science