# Biomedical Imaging

Definition

The science and the branch of medicine concerned with the development and use of imaging devices and techniques to obtain internal anatomic images and to provide biochemical and physiological analysis of tissues and organs.

Discussion

The field of biomedical imaging utilizes advanced technologies to capture, store, analyze and display images at the organ, tissue, cellular, and molecular level. Modalities such as computed tomography, magnetic resonance imaging, molecular imaging, and scanning microscopies play an increasingly important role in clinical practice and basic life sciences research.

Scope and emphasis

Collected comprehensively.

## See also

Bioengineering

Biophysics

Radiology