# Biomathematics

Definition

Biomathematics is the application of mathematics to problems in biology and medicine.

Discussion

Biomathematics is an essential tool in fields such as population genetics, cellular neurobiology, comparative genetics, biomedical imaging, pharmacokinetics, and epidemiology. It plays an increasingly vital role in the effort to understand diseases and disorders, and to improve therapies.

Scope and emphasis

Theoretical and applied biomathematics are comprehensively collected.

## See also

Biomedical Research