# Bioethics

Definition

A branch of applied ethics that studies the value implications of practices and developments in life sciences, medicine, and health care (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D001675)).

Discussion

Bioethics includes literature on the legal and public policy issues surrounding health care and biomedical research.

Scope and emphasis

Collected comprehensively.

## See also

Biotechnology

Government Publications

Medical Sociology

Religion and Medicine