# Bioengineering

Definition:

The application of experimental and analytical techniques based on the engineering sciences to the development of biologics, materials, devices, implants, processes and systems that advance biology and medicine and improve medical practice and health care.

Discussion

Bioengineering is a growing and increasingly interdisciplinary area of research and practice. Recent technological advances have revolutionized the diagnosis and treatment of disease, and provided unprecedented opportunities for conducting biological investigations and improving understanding of fundamental biological processes. Typical areas of research include artificial organs and bionic medicine, tissue engineering and transplant medicine, bioinstrumentation, clinical engineering, biomechanical engineering, biomaterials, nanomedicine, biomolecular engineering, electromagnetic fields in biology and medicine, lasers and optical applications, and ultrasonic applications.

Scope and emphasis

NLM comprehensively collects works in theoretical, experimental and applied studies in bioengineering that further the understanding of living systems or relate directly to or provide models for improvements to human health and health care delivery.

The Library of Congress (http://www.loc.gov/acq/devpol/agri.pdf) and the National Agricultural Library assume responsibility for environmental and agricultural bioengineering.

## See also

Biomedical Imaging

Biophysics

Biotechnology

Toxicology