# Biochemistry

Definition

The chemistry of living organisms and of vital processes.

Scope and emphasis

Collected comprehensively.

## See also

Biotechnology

Chemistry