# Behavioral Medicine

Definition

The interdisciplinary field concerned with the development and integration of behavioral and biomedical science, knowledge, and techniques relevant to health and illness and the application of this knowledge and these techniques to prevention, diagnosis, treatment, and rehabilitation (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D001524)).

Scope and emphasis

Collected comprehensively.

## See also

Psychology