# Audiovisual Media

Consisting of film, video, sound recordings, and projected images, these audiovisual media constitute sources visually documenting the history and development of medicine during the 20^th^ and 21^st^ centuries. The Library is especially interested in the use of audiovisual presentations by medical and health professionals to communicate with each other and with the public, including in the areas of emerging and rare diseases, social determinants of health and well-being, medical education and ethics, patient instruction, technical innovation, health education and advocacy, and leadership in service to science and society.

The Library collects audiovisuals produced for a broad audience, such as televised documentaries and public service announcements, when they are likely to be of historical interest.

For current research and practice, NLM selectively collects works that document contemporary practices and procedures in medicine, health care, and biomedical research. Emphasis is on works which demonstrate innovative techniques or new medical devices, and those which introduce new health policies and guidelines, including measures to uphold trust in biomedical research, reduce health disparities, and increase diversity among professionals serving science and society.

NLM selectively acquires lectures, with emphasis on those delivered by noted persons and others in which audiovisual presentation significantly enhances communication of the topic. Lectures sponsored by NLM, other NIH Institutes and Centers, and authoritative societies and institutions are of particular interest.

Conference publications in audiovisual format are selectively acquired when no textual counterpart exists. Emphasis is on the conference publications of government agencies and other major national and international organizations, in which the audiovisual presentation significantly enhances the communication of important trends, innovations, or discoveries.

The audiovisual collection emphasizes English language audiovisuals produced in the United States. Audiovisuals in foreign languages and non-U.S. works are collected when they contain unique information (e.g., a public health film targeted specifically to U.S. speakers of a foreign language) or are of historical importance.

## See also

Still Image Media

Conference Publications