# Anesthesiology

Definition

The branch of medicine concerned with the relief and prevention of pain during and following surgical, obstetric, therapeutic and diagnostic procedures.

Discussion

Anesthesiology has expanded to include neuroscience and other basic scientific research on pain. Anesthesiologists increasingly are engaged in interdisciplinary clinical fields such as pain management, intensive care, and palliative care.

Scope and emphasis

Collected comprehensively.