# Anatomy

Definition

The study of the structure of the body and the relation of its parts.

Scope and emphasis

The NLM collecting emphasis is on the anatomy of humans, other primates, and laboratory animals.

Special considerations

The Library has an extensive collection of historical anatomical works. Anatomy textbooks are selectively acquired, with emphasis on those most widely used in education for the health professions in the United States.

## See also

Atlases

Textbooks

Veterinary Medicine