# Alumni and Student Publications

Publications written by and for alumni and students often provide information concerning developments in medical education, trace the development of a school, chronicle its history, and report the accomplishments of its alumni, students and staff. To document the history of education in the health professions, NLM very selectively collects alumni and student publications from a range of U.S. institutions, seeking to represent not only the publications of prominent medical schools but also those of culturally and geographically diverse institutions. Selection criteria include the presence of signed original articles, biographical information, and other material of potential historical value.