# Allergy and Immunology

Definition

The branch of medicine concerned with the hypersensitivity of the individual to foreign substances and protection from the resultant infection or disorder (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D000486)).

Scope and emphasis

Collected comprehensively.