# Aerospace Medicine

Definition

The fields of medicine concerned with the maintenance of health, safety and performance of those involved in aviation or space activity.

Scope and emphasis

Collected comprehensively.

## See also

Space Life Sciences