# Results

## Study Identification and Characteristics

The Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) diagrams summarize the results of the literature searches. Electronic databases are shown in Figure 2, and hand searches (comprised of Web searches and articles, abstracts, or posters suggested by peer or public reviewers) are shown in Figure 3. The four database searches yielded a total of 632 records for title and abstract review. We conducted full-text review of 123 articles from the database searches and an additional 27 articles, posters, and abstracts from manufacturers’ Web sites and other sources. A total of 49 articles, posters, or conference abstracts provided evidence for the key questions (KQs) and are included in the review. Appendix C lists the studies and their characteristics. Appendix D lists the quality rating for each study. Appendix E lists studies excluded from the review.

Figure 2 PRISMA for electronic databases

Figure 2 shows the PRISMA diagram that summarizes the results of the electronic database literature search which yielded 772 total articles. The four database searches yielded 632 records for title and abstract review that were not duplicates or protocol reviews. We excluded 392 of these and yielded 123 for full text review. Seventy-seven of these were excluded and 5 were irretrievable with a remaining 41 for abstraction. After excluding seven of these, 34 were included in the report.

Figure 3 PRISMA for hand searches (Web searches and peer/public reviewer)

Figure 3 shows the PRISMA diagram that summarizes the results of the hand searches which yielded 68 total articles. Three of these were irretrievable, leaving 65 for inclusion in the title and abstract review stage. We excluded 38 of these and yielded 27 for full text review. Ten of these were excluded with a remaining 15 for abstraction. Two were excluded at the abstraction stage and 15 abstracted studies were included in the report.

## Key Question 1 What genetic or molecular tissue of origin (TOO) tests are available for clinical use in the United States and what are their characteristics?

We examined commercially available genomic tests that are used to identify the TOO of cancers of unknown primary (CUP) site.

### TOO Tests for CUP

We identified four genetic or molecular tests to determine TOO in CUP cases, one cytogenetic analysis and three genomic assays: PathworkDx from Pathwork Diagnostics, CancerTypeID from Biotheranostics, and miRview mets (original test) and mets^2^ (current test) from Rosetta Genomics (previously marketed in the United States as ProOnc Tumor Source) (Table 5). We also included literature on the Pathwork Tissue of Origin Endometrial Test, used in conjunction with the PathworkDx TOO test to differentiate between tumors of endometrial or ovarian origin. We excluded two TOO tests, CupPrint and Veridex, from the review because they are not available for clinical use in the United States. The CupPrint assay by Agendia was previously available in Europe but is no longer available, and it was never available in the United States. The CUP assay by Veridex was never released for clinical use. We did not include the Caris “Target Now!” because the test identifies likely effective treatment regimens based on biomarkers, not the tumor site of origin.

All TOO tests are currently conducted as a laboratory service: the sample is sent to the test developer, who does the testing and returns a result. The manufacturer of PathworkDx states that kits will be available in the future for labs who wish to do the gene expression analysis in-house and send the data to Pathwork for analysis. Historically, the Food and Drug Administration (FDA), using its enforcement discretion, has regulated very few laboratory-developed tests. Instead, it has focused on regulating tests as medical devices (i.e., a kit or chip for conducting the test). Although FDA is considering modifying the policy,23 it does not currently require companies to apply for FDA approval prior to marketing laboratory-developed tests. PathworkDx requested and received FDA clearance. CancerTypeID, miRview mets, and miRview mets^2^ have not been submitted for FDA review. Although PathworkDx received FDA clearance, the clearance includes limitations on the claims that can be made about the test. These limitations include that the TOO test is not intended: to establish the origin of tumors that cannot be diagnosed according to current clinical and pathological practice; to subclassify or modify the classification of such tumors; to predict disease course, survival, or treatment efficacy; to distinguish primary from metastatic tumors; or to distinguish tumor types in the database from tumor types not in the database.

Analytic and statistical analyses vary between these tests. The PathworkDx and CancerTypeID panels are genes; the assays measure the expression of these genes, the amount of messenger RNA (mRNA). miRview uses microRNAs (miRNAs), which are small, noncoding, single-stranded RNA molecules that regulate genes posttranscription.

PathworkDx uses microarray analysis to measure the expression levels of two large gene panels: a 1,550-gene panel for frozen specimens and a 2,000-gene panel for formalin-fixed paraffin-embedded (FFPE) specimens. The statistical analysis uses pairwise comparisons based on a machine learning algorithm to determine the similarity scores for 15 tumor types. The identified TOO is the tissue type with the highest score above 20.

Table 5 Available genetic or molecular TOO tests for identifying CUPs site and their characteristics

Name of Test | Manufacturer | How Marketed? | FDA Approval | Sample Requirements | Laboratory Analysis Method | Analyte | Panel Size | Number of Tumor Sites Identified | Number of Tumors in Reference Database (Range by Tumor Type) | Reported Results | Statistical Analysis Method
Cancer-TypeID | Biotheranostics | Service | Submitted | FFPE tissue sections or unstained 10 micron sections on glass slides. At least 300–500 viable tumor cells | Quantitative RT-PCR | mRNA | 92 | 28 | 2,206 (26–228)24 | Probability for each cancer type | KNN
Cytogenetic analysis | Multiple cytogenetic laboratories | Service | NA | Fresh tissue | High resolution banded chromosomes | | NA | NA | NA | Karyotype | NA
miRview mets | Rosetta Genomics | Service | Not submitted | Unstained slides, sections in tubes, or FFPE tissue. 2.5 mm^2^ tissue | Microarray platform | miRNA | mets: 48 mets^2^: 64 | mets: 22 mets^2^: 24 | mets: 336 (1–49) mets^2^: 1,282 (NR) | Tumor origin. May list multiple possibilities | Binary decision tree and KNN classifier
PathworkDx TOO Test | Pathwork Diagnostics http://www.pathworkdx.com/ | Service | Cleared | Frozen specimens FFPE or unstained slides. 1 mm^2^ tumor tissue. 30 ng total RNA | Gene expression microarray analysis using cDNA | mRNA | Frozen: 1,550 genes; FFPE: 2,000 genes | 15 | 2,039 (41–444) | Similarity scores | Pairwise comparisons by machine learning algorithm
PathworkDx Endometrial Test | Pathwork Diagnostics http://www.pathworkdx.com/ | Service

Abbreviations: cDNA = complementary deoxyribonucleic acid; FFPA = formalin-fixed paraffin-embedded; GIST = gastrointestinal stromal tumor; KNN = Kohonen neural network; miRNA = micro ribonucleic acid; mRNA = messenger ribonucleic acid; NA = not applicable; RNA = ribonucleic acid; RT-PCR = reverse-transcriptase polymerase chain reaction; TOO = tissue of origin.

CancerTypeID analyzes the expression levels of 92 genes using reverse-transcriptase polymerase chain reaction (RT-PCR). The classification algorithm uses the K-nearest neighbor statistical methodology to determine the probability that a tumor is one of 28 tumor types. The tissue with the highest probability is reported as the most likely TOO with the estimated probability.

The miRview mets used an RT-PCR platform to analyze the expression levels of 48 miRNAs to identify any of 22 tumor sites. The most recent version of the test, miRview mets^2^, used 64 miRNAs to identify 24 tumor types. Both miRview tests use two classification methodologies, a decision tree and a K-nearest neighbor algorithm. If both methodologies give the same result, this result is reported as the TOO. If the two methodologies give different results, both possible TOOs are reported, with the most likely one indicated as the TOO and the other as a less likely TOO.

The type of tumors covered by the three tests varied. All three tests claim to identify cancer of the bladder, breast, kidney, lung, melanoma, ovary, pancreas, prostate, sarcoma, testis, or thyroid (Table 6). Four primary sites identified by all three tests (lung, ovary, pancreas, and prostate) account for 51 percent of primary sites identified at autopsy in series published from 1980 to 2000.^25^

Table 6 Primary tumor sites identified by molecular TOO tests

Primary Site | PathworkDx26 | CancerTypeID26 | miRview mets21
Adrenal | | • | •
Bladder | • | • | •
Brain | | • | •
Breast | • | • | •
Cervix | | •
Cholangiocarcinoma | | • | •
Colorectal | • | • | •
Endometrium | • | •
Esophagus | | •
Gallbladder | | •
Gastric | • | • | •
GIST | | • | •
Head and neck | | • | •
Hepatocellular | • | • | •
Intestine | | • | •
Kidney | • | • | •
Lung | • | • | •
Lymph node | | | •
Melanoma | • | • | •
Meningioma | | •
Mesothelioma | | • | •
Neuroendocrine | | •
Non-Hodgkin’s lymphoma | • | | •
Ovary | • | • | •
Pancreas | • | • | •
Prostate | • | • | •
Sarcoma | • | • | •
Testicle | • | • | •
Thymus | | • | •
Thyroid | • | • | •

Abbreviations: GIST = gastrointestinal stromal tumor; TOO = tissue of origin.

Cytogenetic analysis of tumor cells by G-banded karyotype may also provide information on the TOO in tumors of unknown primary site.14 While cytogenetic abnormalities are common in tumors of all types, certain abnormalities are pathonomic of specific types of cancer.27 These abnormalities, when found, can be used to diagnose the TOO of metastatic tumors.14

## Key Question 2 What is the evidence on the analytic validity of the TOO tests?

Ten studies,24, 28–36 all rated good, provided evidence to answer this KQ. Some data on analytic performance were available for all of the genomic TOO tests. Analytic validity cannot be compared across tests because different data were reported for each test. Results are displayed in Table 7.

### CancerTypeID

One study, rated good, provided information on the analytic validity of the CancerTypeID test.24 Interassay reproducibility was high. Across 194 independent runs with four operators, the mean percentage coefficient of variation (CV) in observed C_t_ for the 92 assay genes compared with the positive control was 1.69 percent. Compared with the negative controls, the mean CV was 1.25 percent. For the 5 normalization genes, the mean CV was 2.19 percent for the positive controls and 1.66 percent for the negative controls.

The variation in the assay across different tumors of the same type was also assessed. Across six tumor types (breast, adrenal, intestine, kidney, thyroid, and prostate), the mean CV for the 92 assay genes was 33 percent; and the mean CV for the 5 normalization genes was 3.16 percent. Each assay includes one sample of known origin. In 32 assays that included three tumor types, the mean CV for the 92 assay genes was 1.58 percent (range 1.41% to 1.69%), and for the 5 normalization genes, it was 1.04 percent (range 0.85% to 1.79%). The assays were 100 percent concordant for the tumor of origin prediction for these samples.

### miRview mets and mets^2^

Four papers,32, 34–36 all rated good, provided information on the analytic validity of the miRview mets and mets^2^ tests. During development of the mets assay, the performance of the microarray platform was validated against RT-PCR analysis.34 The expression distributions and diagnostic roles of the miRNAs were maintained across the platforms. The developers of the test also confirmed that RNA quality and quantity was similar for fresh-frozen, formalin-fixed, and FFPE samples. miRNA profiles were stable in FFPE for up to 11 years.34

Assay quality control measures include a sample with no RNA as a negative control and a well-characterized RNA sample as a positive control. The positive control must meet defined C_t_ ranges. The quality of each well is assessed using the fluorescence amplification curve with thresholds on the linear slope of the curve as a function of the measured C_t_ and maximum fluorescence. The quality of the assay of each sample is assessed on the number and identity of the expressed miRNAs (C_t_ < 38) and the average C_t_ of the measured miRNAs.35, 36 For the second generation assay, the mets^2^ test, the correlation coefficient of multiple assays of the same sample was 0.99. A total of 179 samples were independently tested at both the Rosetta Genomics research and development laboratory and the Clinical Laboratory Improvement Amendments-approved clinical laboratory. Of the 174 samples that passed quality control criteria at both laboratories, 160 samples had an interlaboratory concordance of miRNA expression levels above 95 percent. The laboratories agreed on a diagnosis in 175 of the 179 cases.32

Table 7 Evidence of the analytic validity of the TOO tests

TOO Test, Author, Year Study Dates, Region Quality Rating | Sample Characteristics | Cancer Types | Validity of Marker Measurement | QC Measures for Markers | Assay Accuracy and Precision
CancerTypeID Erlander, 2011^24^ NR Multinational, U.S. Good | Age: Total: 300 Mean (SD): 62 (13) Female: 53% N: Training dataset: N=2,206; Independent sample set: N=187; Clinical cases: N=300 | Adrenal, brain, breast, cervix, cholangiocarcinoma, endometrium, esophagus (squamous cell), gallbladder, gastroesophageal (adenocarcinoma), germ cell, GIST, head/neck, intestine, kidney (renal cell carcinoma), liver, lung, lymphoma, melanoma, meningioma, mesothelioma, neuroendocrine, ovary, pancreas, prostate, sarcoma, sex cord stromal tumor, skin, thymus, thyroid, urinary/bladder | Range of accuracy: NR Range of specificity: NR Number of outliers: NR Cross-reaction with normal tissue: NR | Assay reproducibility (expressed as mean percentage coefficient of variation): Ct values using positive controls (194 independent runs, 4 operators): 92 assay genes: 1.69%; 5 normalization genes: 2.19% Ct values using negative controls (194 independent runs, 4 operators): 92 assay genes:1.25%; 5 normalization genes:1.66% Assays of known tumor types (32 assays, 3 tumor types, 4 scientists) : Mean percentage CVs: 1.58% (range 1.41%–1.69%) for the 92 genes and 1.04% (range 0.85%–1.79%) for the 5 normalization genes 100% concordance for tumor of origin prediction Across tumor type (6 tumor types, 3 setups, 2 operators): 92 assay genes: 3.33%; 5 normalization genes: 3.16% | Required percentage of valid markers: NR QC standards for assay: NR Changes in panel precision and accuracy over time: NR
miRview mets^2^ Meiri, 2012^32^ 1990–2010 NR Good | Age: NR Female: NR N: 509 Interlaboratory correlation: 179 | Adrenal, anus, biliary tract, bladder, brain, breast, cervix, colon/rectum, gastrointestinal, liver, lung, head and neck, esophagus, lymphoma, mesothelioma, ovary, pancreas, prostate, sarcoma, skin, testis, thymus, thyroid | Range of accuracy: NR Range of specificity: NR Number of outliers: NR Cross-reaction with normal tissue: NR | Positive control QA measures: Number of miRNAs with expression > 300 (dynamic range); 98th percentile expression level of the miRNA Pearson correlation between sample and reference hybridization spikes Number of miRNAs with consistent triplicate signals Mean correlations coefficient of multiple assays of same sample: 0.99 Sensitivity: signal at 0.1 fmol with linear dynamic range of 10^3^ Specificity to nucleotide mismatches: 10–100 fold for 1–4 mismatches | Interlaboratory correlation: >0.95 in 89% of samples. Interlaboratory agreement on diagnosis: 175/179 (98%)
miRview mets Rosenfeld, 2008^34^ NR Multinational, not U.S. Good | Age: NR Female: NR N: 80 | Bladder, brain, breast, colon, endometrium, head and neck, kidney, liver, lung, lung pleura, lymph node, melanocytes, meninges, ovary, pancreas, prostate, sarcoma, stomach, GIST, testis, thymus, thyroid | Range of accuracy: NR Range of specificity: NR Number of outliers: NR Cross-reaction with normal tissue: NR | NR | Required percentage of valid markers: NR QC standards for assay: Array platform validated by RT-PCR. miRNA maintained expression distributions and diagnostic roles Changes in panel precision and accuracy over time: NR
miRview mets Rosenwald 2008^35^ NR Multinational, U.S. Good | Age: NR Female: NR N: 853 | Biliary tract, brain, breast, colon, esophagus, head and neck, kidney, liver, lung, melanoma, ovary, pancreas, prostate, stomach, testis, thymus, thyroid | Range of accuracy: NR Range of specificity: NR Number of outliers: NR Cross-reaction with normal tissue: NR | Number and identity of microRNAs (C<38) and average Ct of measured microRNAs. microRNA results consistent across 3 platforms (spotted arrays, custom commercial arrays, and qRT-PCR). Between-lab correlation of qRT-PCR signals per sample=0.98. Labs disagreed on 3 samples; 8 agreed on one answer; 61 matched perfectly. N=72 | Negative control: no RNA sample. Positive control: specific RNA sample that should meet defined range in assay QA based on fluorescence amplification
miRview mets Varadhachary, 2011^36^ 2010 U.S. only Good | Age: Range: 20–83 Median: 58 Female: 66 N: 104 | Lymph nodes, liver, lung, bone, pelvic mass/adnexae, skin/subcutaneous, omentum/peritoneum, adrenal, other | Range of accuracy: NR Range of specificity: NR Number of outliers: NR Cross-reaction with normal tissue: NR | NR | Required percentage of valid markers: 87/104 samples passed tumor content criteria; 74/87 passed all QA criteria QC standards for assay: Controls: No sample; no RNA; external positives. Quality parameters for RNA amplification Changes in panel precision and accuracy over time: NR
PathworkDx Dumur, 2008^30^ NR U.S. only Good | Age: NR Female: NR N: 60 | Breast, colorectal, nonsmall-cell lung, non-Hodgkin’s lymphoma, lymphoma, pancreas, bladder, gastric, germ cell, hepatocellular, kidney, melanoma, ovarian, prostrate, soft tissue, sarcoma, thyroid | Range of accuracy: Pre-standardization 1-to-1 lab correlation, Pearson correlation coefficients 0.65–0.82; Post standardization 1-to-1 lab correlation: 0.81–0.87 Coefficient of reproducibility: 32.48 +/− 3.97 Range of specificity: NR Number of outliers: 19/227 Cross-reaction with normal tissue: NR | All samples with adequate RNA quantity and quality produced sufficient cRNA for hybridization 31/227 samples required >1 labeling reaction Data verification algorithm addresses RNA quality, inadequate amplification, insufficient quantity of labeled RNA, inadequate hybridization time or temperature 218/227 gene expression data files passed verification All 9 failed files showed evidence of RNA degradation | Required percentage of valid markers: NR QC standards for assay: No evidence of bias; similarity score interlaboratory correlation: 0.95; Concordance of physician guided conclusion: 89.4% (range, 87.0–92.5); Kappa>0.86 Changes in panel precision and accuracy over time: NR
PathworkDx Dumur, 2011^29^ NR U.S. only Good | Age: NR Female: NR N: 43 total | Mixed (7 CUP, 6 known off panel, 30 known on panel) | Range of accuracy: NR Range of specificity: NR Number of outliers: NR Cross-reaction with normal tissue: NR | NR | Required percentage of valid markers: ≥40 Percentage of present probes: Mean: 60.6 Range: 49.9–69.3% QC standards for assay: 3´/5´ ratio for glyceraldehyde-3-phosphate dehydrogenase ≤3.0^a^ Mean 3´/5´ GAPDH ratio: 1.2 Range: 0.9–3.0 PathworkDx TOO test report: “Acceptable” data quality
PathworkDx Pillai, 2011^33^ NR U.S. only Good | Age: 10–20: 1 20–30: 19 30–40: 44 40–50: 79 50–60: 133 60–70: 104 70–80: 63 ≥80: 14 Female: 257 Ethnicity: African American:3 Asian/Pacific-Islander: 68 European: 314 N: 462 | Bladder, breast, colorectal, gastric, testicular germ cell, kidney, hepatocellular, nonsmall cell lung cancer, non-Hodgkin’s lymphoma, melanoma, ovarian, pancreatic, prostate, thyroid, and sarcoma | Range of accuracy: overall interlaboratory concordance: 133/149 Range of specificity: NR Number of outliers: NR Cross-reaction with normal tissue: NR | NR | Required percentage of valid markers: Percentage present ≥5 Overall signal (mean summarized expression value of all probes) ≥10, Regional discontinuity (correlation between intensity of probe and mean of two adjacent probes) ≤0.84 QC standards for assay: between-laboratory reproducibility of results: Overall concordance between SS scores: 89.3; Correlation coefficients for SS scores: 0.92–0.93; Slopes: 0.93–0.96; Kappa analysis of intersite agreement: 0.85–0.92; Bland-Altman analysis for systematic bias: <10% of specimens outside 95% limit of agreement; Overall signal ≥10 Changes in panel precision and accuracy over time: No change in test performance by age of specimen
Pathwork Tissue of Origin Endometrial Test Lal, 2012^31^ NR U.S. only Good | Age, n of subjects in age range 30–50: 9 50–60: 24 60–70: 28 70–90: 14 Female: NR N: 75 | Ovarian, endometrial | NR | NR | Intrasite reproducibility=46/46 Concordance percentage: 100% (95% CI: 92.3–100) Intersite reproducibility=83/88 Concordance percentage: 94.3% (95% CI: 87.2–98.1) Median coefficient of variation (CV%) of the similarity score: 1.38 (range 0.32–8.79) Kappa (Κ) statistic: 1.0 for all three pairwise comparisons. Changes in panel precision and accuracy over time: Test performance 90.5% for specimens >2 years old

a Article states 3.0 or more, but usual standard is 3.0 or less.

Abbreviations: CI = confidence interval; cRNA = complementary RNA; Ct = cycle threshold; CV = coefficient of variation; n = number; N = number; GAPDH = glyceraldehyde-3-phosphate dehydrogenase; GIST = gastrointestinal stromal tumor; NR = not reported; mRNA = micro ribonucleic acids; QA = quality assurance; QC = quality control; qRT-PCR = quantitative reverse transcriptase polymerase chain reaction; RNA = ribonucleic acid; RT-PCR = reverse transcriptase polymerase chain reaction; SD = standard deviation; SS = similarity score; TOO = tissue of origin; U.S. = United States.

### PathworkDx

Three studies,29, 30, 33 all rated as good, provided information on the analytic validity of the PathworkDx test. The PathworkDx data verification algorithm assesses assay quality, including quality of RNA, adequacy of RNA amplification, quantity of labeled RNA, and adequacy of hybridization time and temperature.30 Assay data quality is assessed by three statistics: overall signal, percent present, and regional discontinuity. Overall signal is the mean summarized expression value of all probes; it must be ≥10. Percent present is the percentage of probes sets assigned a present call by the Affymetrix MAS 5.0 algorithm; it must be ≥5. Regional discontinuity is the correlation between a probe’s intensity and the mean intensity of the two adjacent probes. Regional discontinuity must be ≤0.84. The age of the sample did not affect assay performance.33 In their clinical validation study, Dumur et al.29 assessed assay quality by the percent of present probes and the 3’/5’ ratio of the housekeeping gene glyceraldehyde-3-phosphate dehydrogenase (GAPDH). The mean percentage of present probes was 60.6 (range: 49.9 to 69.3), and the mean 3’/5’ GAPDH ratio was 1.2 (range: 0.9 to 3.0).

Two multisite studies30, 33 assessed analytic validity and interlaboratory correlation. In the study by Dumur et al.,30 218 of 227 (96%) gene expression data files passed verification. All 9 failed files showed evidence of RNA degradation. Interlaboratory correlation was high; the Pearson correlation coefficients of between-laboratory Affymetrix normalized gene expression values were 0.65 to 0.82. After standardization with the PathworkDx TOO algorithm, the correlation coefficients ranged from 0.81 to 0.87. The calculated similarity scores (SS) were even more highly correlated; all comparisons had a Pearson correlation coefficient above 0.95. The overall between-laboratory concordance on the final TOO call was 89.4 percent (range: 87.0 to 92.5), and the kappa analysis indicated that agreement was very good (κ>0.86). The Bland-Altman analysis found a high level of agreement (coefficient of reproducibility 32.48±3.97) and indication of no systematic bias (<10% of specimens outside 95% limit of agreement).30 Pillai et al.33 also found strong correlation between laboratories. The overall concordance in SS between the three laboratories was 89.3 percent. The correlation coefficients for the SS ranged from 0.92 to 0.93, and the kappa statistic for interlaboratory agreement ranged from 0.85 to 0.92.

### Cytogenetic Analysis

We found no papers that specifically examined the analytic validity of cytogenetic analysis in the context of tumors of unknown primary site.

## Key Question 3a What is the evidence on the accuracy of the TOO test in classifying the origin and type of the tumor? Did the statistical methods adhere to the guidelines published by Simon et al. (2003)?

Six studies graded as good provided evidence on this question. We were able to assess the validity of the statistical algorithm for CancerTypeID and miRview but not for PathworkDx TOO test. Figures 4 through 6 display the accuracy estimates with 95% confidence intervals (CIs) for the three tests. The results are displayed in Table 8.

Table 8 Evidence of accuracy of TOO test in classifying the origin and type of the tumor and statistical methods’ adherence to Simon guidelines

TOO Test, Author, Year Study Dates, Region, Quality Rating | Sample Characteristics | Cancer Types | Normalization Methodology | Dimension Reduction Methodology | Classification Rule Supervision | Internal and External Validation Methods
CancerTypeID Ma, 2006^37^ NR U.S. only | Age: NR Female: NR N: 578 | Adrenal, brain, breast, intestine, cervix, endometrium, gallbladder, ovary, gastrointestinal, kidney, leiomyosarcoma, liver, lung, lymphoma, meningioma, mesothelioma, osteosarcoma, pancreas, prostate, skin, small and large bowel, soft tissue, stomach, testis, thyroid, urinary/bladder | Total expression: Raw Cy5/Cy3 ratios normalized using nonlinear local regression, without background adjustment | Hypothesis tests: Logistic regression Ranking: NR Clustering : NR | Supervised: K-nearest neighbors (KNN) | Internal: Leave-one-out cross-validation to select genes; Multiclass weighted KNN classification algorithm to classify genes; Gene selection also done via genetic algorithm External: Validation study of 187 FFPE tumor samples
miRview mets Rosenfeld, 2008^34^ NR Multinational, not U.S. Good | Age: NR Female: NR N: 253 learning set 83 validation set | Bladder, brain, breast, colon, endometrium, head and neck, kidney, liver, lung, lung pleura, lymph node, melanocytes, meninges, ovary, pancreas, prostate, sarcoma, stomach, GIST, testis, thymus, thyroid | Total expression: Based on median expression level for each probe across all samples | Hypothesis tests: NR Ranking: NR Clustering : NR | Supervised: Decision-tree KNN | Internal: Leave-one-out cross-validation within the training set External: Blinded test set with independent set of 83 samples
miRview mets Rosenwald, 2010^35^ NR Multinational, U.S. Good | Age: NR Female: NR N: 649 learning set 204 validation | Biliary tract, brain, breast, colon, esophagus, head and neck, kidney, liver, lung, melanoma, ovary, pancreas, prostate, stomach or esophagus, testis, thymus, thyroid | Total expression: Average expression of all microRNAs + scaling constant (the average expression over the entire sample set) | Hypothesis tests: NR Ranking: Decision tree algorithm selected 48 miRNAs through feature selection Clustering: NR | Supervised: Binary decision tree KNN | Internal: Leave-one-out cross validation within the training set External: Test performance assessed using independent set of 204 validation samples
PathworkDx Dumur, 2008^30^ NR U.S. only Good | Age: NR Female: NR N: 60 | Breast, colorectal, nonsmall-cell lung, non-Hodgkin’s lymphoma, lymphoma, pancreas, bladder, gastric, germ cell, hepatocellular, kidney, melanoma, ovarian, prostrate, soft tissue, sarcoma, thyroid | Total expression: NR Selected housekeeping: 121 mRNA markers stably expressed across cell types | Hypothesis tests: NR Ranking: NR Clustering : NR | Unsupervised: NR Supervised: NR | Internal: NR External: Validated by Pillai et al. 33
PathworkDx Pillai, 2011^33^ NR U.S. only Good | Age: 10–20: 1 20–30: 19 30–40: 44 40–50: 79 50–60: 133 60–70: 104 70–80: 63 ≥80: 14 Female: 257 N: 462 | Bladder, breast, colorectal, gastric, testicular germ cell, kidney, hepatocellular, nonsmall cell lung cancer, non-Hodgkin’s lymphoma, melanoma, ovarian, pancreatic, prostate, thyroid, sarcoma | Total expression: NR Selected housekeeping: 121 mRNA markers stably expressed across cell types | Hypothesis tests: NR Ranking: NR Clustering : NR | Unsupervised: NR Supervised: NR | Internal: NR External: Multisite validation study
PathworkDx Lal, 2012^31^ NR Multisite Good | Age: NR Female: NR N: 849 | Ovarian and endometrial | Total expression: NR Selected housekeeping: 59 genes | Hypothesis tests: NR Ranking: NR Clustering : NR | Unsupervised: Machine learning | Internal: NR External: Validated with blinded test set of 75 tumors

Abbreviations: FFPE = formula fixed paraffin embedded; GIST = gastrointestinal stromal tumor; KNN = K-nearest neighbor; mRNA = microRNA; N = number; NR = not reported; TOO = tissue of origin; U.S. = United States.

### CancerTypeID

#### Normalization

Five of the 92 genes in the assay are reference genes that are used to normalize expression levels of the 87 genes used to classify tissues into the 39 tumor types. One study,37 graded good, reported that the selection of the 5 reference genes for normalization was based on the relatively constant expression levels of these genes across all tumor types. As discussed in Czechowski et al. (2005),38 although this is a common way to normalize gene expression data, unless the genes were identified as stable across multiple types of tissues and experimental conditions, it is difficult to know whether these genes are indeed stable across all conditions. There is not sufficient information in the publication to assess if the stability of the genes were assessed in this way.

#### Dimension Reduction

The dimension reduction algorithm developed used a combination of k-nearest neighbor (KNN) and a genetic algorithm to identify clusters of related genes. The identified genes were then used in a general linear model to assess the predictive ability of the cluster. Multiple iterations of the process resulted in the set of 87 genes used in the final test. This method uses repeated combinations of unsupervised and supervised clustering to identify a subset of gene profiles that would perform well in clusters.

#### Classification

The classification algorithm used here is a logistic regression model that is equivalent to a linear discriminant classifier. This classifier uses supervised learning and is the optimal method of classification per Simon et al.18 First described in Ma et al.,37 a modification of the process was described in Erlander et al.24 (which was also graded as a good study). The modification described in Erlander et al.24 adds the classification of the cancer subtype to the algorithm.

#### Validation

The algorithm for CancerTypeID was described first in Ma et al.37 and then in Erlander et al.24 Both studies reported internal validation using a leave one out cross validation and a separate validation in an independent test set. Simon et al.18 suggest using at least one of the two types of validation in algorithm development and validation in an independent test set as optimal. This test meets both criteria.

### miRview

#### Normalization

A study graded good34 reported that a two-degree polynomial that optimized the fit between a reference vector that contained median expression levels for all miRNAs in each sample and the sample data was identified. The polynomial was used to transform the raw expression level of each probe to its normalized value.

#### Dimension Reduction

The algorithm used stepwise logistic regression to create a decision tree in which the nodes were the tumor types. The model assessed the predictive values of miRNAs to predict a tumor type. The process started with one miRNA and added more if the difference in the log likelihood of the new model and old model resulted in a chi-square value of 7.82 (p<0.0005). To mitigate the small number of samples for different tissue types, the logistic regression was repeatedly fit to bootstrapped samples that included two-thirds of the original sample. The use of logistic regression as the discriminator at nodes allowed the introduction of clinical features into the decision tree. This is an appropriate method and avoids many of the issues that are discussed by Simon et al.18 with respect to the use of clustering methods and fold change as a means of dimension reduction.

#### Classification

The classification used in the algorithm also uses a decision tree with logistic regression to separate the nodes and combines the decisions of the decision tree with an unsupervised KNN classifier. The combination of a supervised and unsupervised method along with both internal and external validation meets the Simon criteria.18

#### Validation

In addition to using a leave one out cross validation, Rosenfeld et al.34 reported validation using a blinded independent data set of 83 cases randomly selected before developing the classifier from the sample of the data. In addition, they validated the utility of the miRNAs using an RT-PCR platform and an additional 80 samples, including 65 independent samples. Simon et al.18 suggest using at least one of the two types of validation in algorithm development and validation in an independent test set as optimal. This test meets both criteria.

### PathworkDx

#### Normalization

As reported in Dumur et al.30 and Pillai,33 which were both rated as good, gene expression levels were normalized to a set of 121 stable markers that were identified as being stable across 5,000 tissue specimens processed in 11 laboratories. The process was developed as a part of the Micro Array Quality Control project and is an appropriate way to normalize microarray data.

#### Dimension Reduction

The dimension reduction algorithm is based on ranking genes based on expression levels. There was no description of the dimension reduction algorithm beyond that in either Dumur et al.30 or Pillai,33 which makes it difficult to assess its validity.

#### Classification

The classification uses a proprietary machine learning algorithm that compares the expression profile of the patient tissue with that of profiles of 15 cancer types. Once again, there was little detail in the publications, and it is not possible to independently assess the validity of the classifier.

#### Validation

Simon et al.18 suggest using at least one of the two types of validation in algorithm development and validation in an independent test set as optimal. There was no information on the internal and external validation used during the development of the algorithm used in PathworkDx TOO. However, several retrospective studies, as well as a blinded prospective study, have validated this test. As described below, the studies reported rates of accuracy between 74 percent and 99 percent.

### Pathwork Endometrial

Pathwork Endometrial is a new test similar to the PathworkDx TOO described above but designed to distinguish only between ovarian and endometrial sites of origin. Lal et al., (2012)31 in a study graded good, described the development and validation of the test. Details on normalization, dimension reduction, and development of the classifier were scarce, making it difficult to independently assess the validity of the statistical process used to develop the tests. The validation was conducted as recommended by Simon et al.18 in an independent sample of 75 tissues (45 endometrial and 30 ovarian).

### Cytogenetic Analysis

Statistical algorithms are not used in cytogenetic analysis.

## Key Question 3b What is the evidence on the accuracy of the TOO test in classifying the origin and type of the tumor?

Twenty studies,24, 29–35, 37, 39–49 nineteen24, 29–35, 37, 39–44, 46–49 rated good and one rated fair,45 provided responses to this question. Three or more studies reported on the accuracy of each of the three tests. The accuracy rates across all of the studies for each of the three tests were fairly consistent. The meta-analytic summary of accuracy for the three tests were as follows: CancerTypeID 85 percent (95% CI, 83% to 86%), miRview 85 percent (95% CI, 83% to 87%), and PathworkDx 88 percent (95% CI, 86% to 89%).

The results are displayed in Table 9, Table 10, and Table 11.

### CancerTypeID

#### Accuracy

Six studies24, 37, 41, 42, 47, 49 reported on the accuracy of the test. Ma et al.,37 graded good, reported an overall accuracy of 82 percent (95% CI, 74% to 89%) in an independent test set with 119 tissues of known origin. Site-specific accuracy ranged from 0 to 100 percent (Table 11). Erlander et al.,24 graded good, reported an overall accuracy of 83 percent (95% CI, 78% to 88%) on a test set of tissue. Site-specific accuracy (Table 11) ranged from 50 to 100 percent. In a study graded good, Kerr et al.42 reported an overall accuracy rate of 87 percent (95% CI, 84% to 89%) in a multi-institutional cohort of 790 tissues of known origin. The diagnosis of the tissues was adjudicated prior to blinded testing with CancerTypeID. Site-specific accuracy (Table 11) ranged from 48 to 100 percent. In a separate study graded good, focused on neuroendocrine tumor subtyping, Kerr et al.41 reported an accuracy rate of 95 percent in a sample of 75 tissues of neuroendocrine carcinoma. CancerTypeID correctly identified the tumor subtype in 71 of the 75 tissues. In a study rated good that compared the accuracy of immunohistochemical (IHC) staining against the accuracy of CancerTypeID, Weiss et al.47 reported a 78 percent accuracy rate for CancerTypeID compared with 68 percent for IHC in a sample of 123 tissues. In a study, rated good, to assess the accuracy of CancerTypeID in a Chinese population, Wu et al.49 reported an accuracy rate of 82 percent in a sample of 184 tissues that represented 23 sites of origin. Site-specific accuracy (Table 11) ranged from 64 to 100 percent. Figure 4 displays the accuracy estimates across these seven studies.

Figure 4 Point estimates and 95% confidence intervals for all the reviewed studies estimating accuracy in known tissue for CancerTypeID TOO

Figure 4 has the proportion of known tissue that were accurately identified by CancerTYpe ID in the six studies reviewed for KQ3a. The X axis has the authors and year of the studies; the y-axis has the accuracy estimates.

Table 9 Evidence of accuracy of the TOO test in classifying the origin when compared with gold standard

TOO Test, Author, Year Study Dates, Region, Quality Rating | Sample Characteristics | Cancers Included | Gold Standard (comparison test) | Sensitivity % (95% CI) | Specificity % (95% CI)
CancerTypeID Erlander, 2011^24^ NR Multinational, U.S. Good | Age: NR Female: NR N: 187 | Adrenal, brain, breast, cervix, cholangiocarcinoma, endometrium, esophagus (squamous cell), gallbladder, gastroesophageal (adenocarcinoma), germ cell, GIST, head/neck, intestine, kidney (renal cell carcinoma), liver, lung, lymphoma, melanoma, meningioma, mesothelioma, neuroendocrine, ovary, pancreas, prostate, sarcoma, sex cord stromal tumor, skin, thymus, thyroid, urinary/bladder | Known origin | 83 (78–88) | 99 (99–99)
CancerTypeID Kerr, 2012^42^ NR NR Good | Age in ranges: <50: 203 50–64: 271 >64: 316 Female: 405 N: 790 | Metastatic tumors and moderately to poorly differentiated primary tumors of the following types: Adrenal, brain, breast, cervix adenocarcinoma, endometrium, gastroesophageal, germ cell, GIST, head-neck-salivary. Intestine, kidney, liver, lung-adeno/large cell, lymphoma, melanoma, meningioma, mesothelioma, neuroendocrine, ovary, pancreaticobiliary, prostate, sarcoma, sex cord stromal tumor, skin basal cell, squamous, thymus, thyroid, urinary/bladder | Diagnosis adjudicated prior to blind TOO testing | 87 (84–89) | Incorrect exclusion: 5% cases
CancerTypeID Kerr, 2012^41^ NR U.S. only Good | Age: NR Female: NR N: 75 | Neuroendocrine carcinoma | Clinicopathologic diagnoses | 95 | NR
CancerTypeID Ma, 2006^37^ NR U.S. only Good | Age: NR Female: NR N: 119 | Adrenal, brain, breast, intestine, cervix, endometrium, gallbladder, gastrointestinal stromal tumor of stomach, kidney, leiomyosarcoma, liver, lung, lymphoma, lymphoma, meningioma, mesothelioma, osteosarcoma, ovary, pancreas, prostate, skin, small and large bowel, soft-tissue, stomach, testis, thyroid, urinary/bladder | Known origin | 82 (74–89) | NR
CancerTypeID Weiss, 2012^47^ NR U.S. Good | Age: Mean (SD): 61.2 (14.4) years Female: 52% N: 123 | Metastatic | Final clinicopathological diagnosis | IHC: 68 CTID: 78 p=0.017 | NR
CancerTypeID Wu, 2012^49^ NR China Good | Age: NR Female: 94 Ethnicity: Chinese N: 184 | Adrenal, breast, endometrium, gallbladder, gastroesophageal germ cell, GIST, head and neck, intestine, kidney, liver, lung, lymphoma, melanoma, mesothelioma, neuroendocrine, ovary, pancreas, prostate, sarcoma, skin, thyroid, urinary/bladder | Clinicopathological diagnosis | 82.1 (151/184) | NR
miRview mets^2^ Meiri, 2012^32^ 1990–2010 NR Good | Age: NR Female: NR N: 509 | Adrenal, anus, biliary tract, bladder, brain, breast, cervix, colon/rectum, gastrointestinal, liver, lung, head and neck, esophagus, lymphoma, mesothelioma, ovary, pancreas, prostate, sarcoma, skin, testis, thymus, thyroid | Known origin | Single or one of two predictions: 85.5 (418/489) Single prediction made: 89.6 (361/403) | >99
miRview mets Mueller, 2011^45^ 2008 Germany Fair | Age: NR Female: NR N: 102 | Biliary tract, breast, colon, head and neck, kidney, liver, lung, melanocyte, ovary, stomach or esophagus, thyroid, | Known origin | Single or one of two predictions: 84 (75/89) Single prediction: 88 (46/52) | 95 Single prediction: 99
miRview mets Rosenfeld, 2008^34^ NR Multinational, not U.S. Good | Age: NR Female: NR N: 83 | Bladder, brain, breast, colon, endometrium, head and neck, kidney, liver, lung, lung pleura, lymph node, melanocytes, meninges, ovary, pancreas, prostate, sarcoma, stomach, stromal, testis, thymus, thyroid | Known origin | Single or one of two predictions: 86 Decision tree: 72 KNN: 72 | Single or one of two predictions: 99 Decision tree: 99
miRview mets Rosenwald, 2010^35^ NR Multinational, U.S. Good | Age: NR Female: NR N: 504 | Bladder, brain, breast, colon, endometrium, head and neck, kidney, liver, lung, lung pleura, lymph node, melanocytes, meninges, ovary, pancreas, prostate, sarcoma, stomach, stromal, testis, thymus, thyroid | Known origin | Single or one of two predictions: 84.6 Single prediction: 89.5 | Single or one of two predictions: 96.9 Single predictions: 99.3
PathworkDx Beck, 2011^39^ NR U.S. only Good | Age: NR Female: NR N: 49 | Bladder, breast, colorectal, gastric, hepatocellular, liver, melanoma, ovarian, pancreatic, prostate, renal, synovial sarcoma, sarcoma, thyroid | Known origin | 29/39 (74%) Indeterminate: 7/39 (18%) Incorrect: 3/39 (7%) | NR
PathworkDx Dumur, 2008^30^ NR U.S. only Good | Age: NR Female: NR N: 60 | Breast, colorectal, nonsmall cell lung, non-Hodgkin’s lymphoma, lymphoma, pancreas, bladder, gastric, germ cell, hepatocellular, kidney, melanoma, ovarian, prostrate, soft tissue, sarcoma, thyroid | Known origin | All samples (range): 86.7% (84.9–89.3%) Samples within manufacturer’s tissue quality control parameters: Average (range): 93.8 (93.3–95.5%) Indeterminate: 5.5% to 11.3% | NR
PathworkDx Dumur, 2011^29^ NR U.S. only Fair | Age: NR Female: NR N: 43 | Mixed (7 CUP, 6 known off panel, 30 known on panel) | Clinicopathologic diagnosis | Agreed: Known on-panel: 97 (28/29) 95% CI (80.4–99.8) | NR
PathworkDx Grenert, 2011^40^ 2000–2007 U.S. only Good | Age: Range 22–74 Median 55 Female: 20 N: 37 | Bladder, breast, colorectal, gastric, testicular germ cell, kidney, hepatocellular, nonsmall cell lung, non-Hodgkin’s lymphoma, melanoma, ovarian, pancreas, prostate, sarcoma, thyroid | Clinicopathologic diagnosis | 95 (95% CI: 81.8–99.3) | 99.60
Pathwork Tissue of Origin Test Kulkarni, 2012^43^ 2007–2011 U.S. only Good | Age: NR Female: 3 N: 10 | Metastatic tumors from clinically identified primary site not diagnosed by IHC alone | Final clinicopathological diagnosis | Correct diagnosis: TOO: 9/10 (90%) Overall pathologist (5) review of IHC (10 cases): 32 /50 (64%) Individual pathologists: range 5/10–8/10 | NR
PathworkDx Monzon, 2009^44^ NR Multinational, U.S. Good | Age: < 50: 142 50–59: 133 60–69: 139 ≥ 70: 132 Female: 290 N: 547 | Colorectal, pancreatic, nonsmall cell lung, breast, gastric, kidney, hepatocellular, ovary, sarcoma, non-Hodgkin’s lymphoma, thyroid, prostate, melanoma, bladder, testicular germ cell | Known origin | 480/547 (87.8) (84.7 – 90.4) | 99.4
PathworkDx Pillai, 2011^33^ NR U.S. only Good | Age: 10–20: 1 20–30: 19 30–40: 44 40–50: 79 50–60: 133 60–70: 104 70–80 : 63 ≥80: 14 Female: 257 N: 462 | Bladder, breast, colorectal, gastric, testicular germ cell, kidney, hepatocellular, and nonsmall cell lung cancer, non-Hodgkin’s lymphoma, melanoma, ovarian cancer, pancreatic cancer, prostate cancer, thyroid cancer, and sarcoma | Known origin | 409/462 (88.5) (85.3–91.3) | 99.1
PathworkDx Stancel, 2011^46^ NR U.S. only Good | Age: NR Female: NR N: 20 | Lung, lymphoma, colon, pancreas, breast, ovarian, gastric | Known origin | 15/19 (78.9%) | NR
PathworkDx Wu, 2010^48^ NR U.S. only Good | Age: Median: 41 Range: 21–56 Female: 3 N: 15 | Lung, breast, melanoma, lymphoma, sarcoma, colon, head and neck, gastric, kidney | Known origin | 12/13 (92%) | NR
Pathwork Tissue of Origin Endometrial Test Lal, 2012^31^ NR U.S. only Good | Age, n of subjects in age range 30–50: 9 50–60: 24 60–70: 28 70–90: 14 Female: 75 N; 75 | Ovarian and endometrial | Clinical diagnosis | 71/75 (94.7) (86.9–98.5) AUC: 0.997

Abbreviations: AUC = area under receiver operating cure; CI = confidence interval; CTID = CancerTypeID; GIST = gastrointestinal stromal tumor; IHC = immunohistochemistry; n = number; N = number; NR = not reported; TOO = tissue of origin; U.S. = United States.

Table 10 Meta-analysis estimates of accuracy of TOO tests in identifying the TOO of tumors of known origin

TOO Test | Summarized Estimate of Accuracy | 95% CI, Lower Bound | 95% CI Upper Bound
CancerTypeID | 0.85 | 0.83 | 0.86
miRview | 0.85 | 0.83 | 0.87
PathworkDx | 0.88 | 0.86 | 0.89

Abbreviations: CI = confidence interval; TOO = tissue of origin.

Table 11 Evidence of site-specific accuracy of TOO test in classifying type of the tumor

TOO Test, Author, Year Study Dates, Region, Quality Rating | Sample Characteristics | Cancer/Tumor Site | Sample Size | Sensitivity | Specificity
CancerTypeID Erlander, 2011^24^ NR Multinational, U.S. Good | Age: NR Female: NR N: 187 | 1. Adrenal 2. Brain 3. Breast 4. Cholangio-carcinoma 5. Endometrium 6. Gallbladder 7. Gastroesophageal 8. Germ cell 9. GIST 10. Head/neck 11. Intestine 12. Kidney 13. Liver 14. Lung 15. Lymphoma 16. Melanoma 17. Meningioma 18. Mesothelioma 19. Neuroendocrine 20. Ovary 21. Pancreas 22. Prostate 23. Sarcoma 24. Sex cord stromal tumor 25. Skin 26. Thymus 27. Thyroid 28. Urinary/bladder | 1. 2 2. 5 3. 11 4. 7 5. 4 6. 6 7. 14 8. 6 9. 1 10. 13 11. 16 12. 5 13. 7 14. 13 15. 10 16. 5 17. 1 18. 2 19. 7 20. 6 21. 8 22. 8 23. 6 24. 1 25. 9 26. 2 27. 5 28. 7 | 1. 1.00 2. 1.00 3. 1.00 4. 0.71 5. 0.75 6. 0.67 7. 0.86 8. 1.00 9. 1.00 10. 0.54 11. 0.63 12. 1.00 13. 1.00 14. 0.92 15. 1.00 16. 0.80 17. 1.00 18. 1.00 19. 1.00 20. 0.83 21. 0.63 22. 0.88 23. 1.00 24. 1.00 25. 0.67 26. 0.50 27. 1.00 28. 0.86 | 1. 1.00 2. 1.00 3. 1.00 4. 0.99 5. 0.99 6. 0.98 7. 0.97 8. 0.98 9. 1.00 10. 0.99 11. 1.00 12. 1.00 13. 1.00 14. 0.98 15. 0.99 16. 1.00 17. 1.00 18. 0.99 19. 1.00 20. 0.99 21. 0.99 22. 1.00 23. 0.99 24. 1.00 25. 0.99 26. 1.00 27. 1.00 28. 0.99
CancerTypeID Kerr, 2012^42^ NR NR Good | Age in ranges: <50: 203 50–64: 271 >64: 316 Female: 405 N: 790 | 1. Adrenal 2. Brain 3. Breast 4. Cervix adenocarcinoma 5. Endometrium 6. Gastroesophageal 7. Germ cell 8. GIST 9. Head-neck-salivary 10. Intestine 11. Kidney 12. Liver 13. Lung-adeno/large cell 14. Lymphoma 15. Melanoma 16. Meningioma 17. Mesothelioma 18. Neuroendocrine 19. Ovary 20. Pancreaticobiliary 21. Prostate 22. Sarcoma 23. Sex cord stromal tumor 24. Skin basal cell 25. Squamous 26. Thymus 27. Thyroid 28. Urinary/bladder | 29. 25 30. 25 31. 25 32. 25 33. 25 34. 25 35. 25 36. 25 37. 25 38. 25 39. 30 40. 25 41. 25 42. 25 43. 25 44. 25 45. 25 46. 50 47. 40 48. 30 49. 25 50. 60 51. 25 52. 25 53. 30 54. 30 55. 25 56. 25 | 57. 0.96 (0.80–1.00) 58. 0.96 (0.80–1.00) 59. 0.80 (0.56–0.94) 60. 0.72 (0.47–0.90) 61. 0.48 (0.26–0.70) 62. 0.65 (0.41–0.85) 63. 0.83 (0.61–0.95) 64. 0.92 (0.74–0.99) 65. 0.88 (0.68–0.97) 66. 0.85 (0.62–0.97) 67. 0.97 (0.83–1.00) 68. 0.96 (0.80–1.00) 69. 0.65 (0.43–0.84) 70. 0.84 (0.64–0.95) 71. 0.88 (0.69–0.97) 72. 1.00 (0.80–1.00) 73. 0.87 (0.66–0.97) 74. 0.98 (0.89–1.00) 75. 0.86 (0.71–0.95) 76. 0.88 (0.68–0.97) 77. 1.00 (0.80–1.00) 78. 0.95 (0.86–0.99) 79. 0.80 (0.59–0.93) 80. 1.00 (0.80–1.00) 81. 0.86 (0.68–0.96) 82. 0.72 (0.51–0.88) 83. 0.96 (0.80–1.00) 84. 0.64 (0.41–0.83) | 85. 0.99 (0.98–1.00) 86. 1.00 (0.99–1.00) 87. 1.00 (0.99–1.00) 88. 0.99 (0.99–1.00) 89. 1.00 (0.99–1.00) 90. 0.99 (0.99–1.00) 91. 1.00 (0.99–1.00) 92. 1.00 (0.99–1.00) 93. 0.99 (0.98–1.00) 94. 0.98 (0.97–0.99) 95. 1.00 (0.99–1.00) 96. 1.00 (0.99–1.00) 97. 1.00 (0.99–1.00) 98. 1.00 (0.99–1.00) 99. 1.00 (0.99–1.00) 100. 1.00 (0.99–1.00) 101. 1.00 (0.99–1.00) 102. 1.00 (0.99–1.00) 103. 0.98 (0.97–0.99) 104. 0.99 (0.98–1.00) 105. 1.00 (0.99–1.00) 106. 0.99 (0.97–0.99) 107. 1.00 (0.99–1.00) 108. 1.00 (0.99–1.00) 109. 0.98 (0.97–0.99) 110. 1.00 (0.99–1.00) 111. 1.00 (0.99–1.00) 112. 0.99 (0.98–1.00)
CancerTypeID Kerr, 2012^41^ NR U.S. only Good | Age: NR Female: NR N: 75 | 1. Intestinal 2. Lung high grade 3. Lung low grade 4. Merkel cell 5. Pancreas 6. Pheo/paraganglioma 7. Thyroid medullary | 1. 12 2. 11 3. 11 4. 10 5. 10 6. 10 7. 11 | 1. 12/12 1.00 2. 11/10 0.91 3. 11/10 0.91 4. 10/10 1.00 5. 10/8 0.80 6. 10/10 1.00 7. 11/11 1.00 | 1. 1.00 2. 1.00 3. 1.00 4. 0.97 5. 0.98 6. 1.00 7. 1.00
CancerTypeID Ma, 2006^37^ NR U.S. only Good | Age: NR Female: NR N: 119 | 1. Adrenal 2. Brain 3. Breast 4. Carcinoid–intestine 5. Cervix–adeno 6. Cervix–squamous 7. Endometrium 8. Gallbladder 9. Germ cell 10. GIST 11. Kidney 12. Leiomyosarcoma 13. Liver 14. Lung–adeno–large cell 15. Lung–small 16. Lung–squamous 17. Lymphoma 18. Meningioma 19. Mesothelioma 20. Osteosarcoma 21. Ovary 22. Pancreas 23. Prostate 24. Skin–basal cell 25. Skin–melanoma 26. Skin–squamous 27. Small and large bowel 28. Soft-tissue 29. Stomach–adeno 30. Thyroid–follicular–papillary 31. Thyroid–medullary 32. Urinary/bladder | 1. 1 2. 3 3. 1 4. 2 5. 2 6. 3 7. 3 8. 0 9. 9 10. 3 11. 4 12. 3 13. 2 14. 3 15. 5 16. 3 17. 10 18. 3 19. 5 20. 2 21. 5 22. 3 23. 7 24. 4 25. 4 26. 3 27. 6 28. 8 29. 3 30. 3 31. 0 32. 6 | 1. 1.00 2. 1.00 3. 1.00 4. 1.00 5. 0.50 6. 0.67 7. 0.67 8. - 9. 0.78 10. 1.00 11. 1.00 12. 0.33 13. 1.00 14. 0.00 15. 0.40 16. 1.00 17. 1.00 18. 1.00 19. 0.80 20. 1.00 21. 1.00 22. 1.00 23. 1.00 24. 0.75 25. 0.75 26. 1.00 27. 0.83 28. 0.88 29. 0.00 30. 1.00 31. - 32. 1.00 | NR
CancerTypeID Weiss, 2012^47^ NR U.S. | Age: Mean (SD): 61.2 (14.4) years Female: 52% N: 123 | 1. Lung 2. Urinary/bladder 3. Breast 4. GI 5. Kidney | NR | 1. CTID: 0.75, IHC: 0.67 2. CTID: 0.75, IHC: 0.42 3. CTID: 0.73, IHC: 0.55 4. CTID: 0.77, IHC: 0.77 5. CTID: 0.77, IHC: 0.77 | NR
Cancer TypeID Wu, 2012^49^ NR China Good | Age: NR Female: 94 N: 184 | 1. Adrenal 2. Breast 3. GIST 4. Intestine 5. Liver 6. Lymphoma 7. Prostate 8. Thyroid 9. Germ cell 10. Neuroendocrine 11. Kidney 12. Lung 13. Skin 14. Gallbladder 15. Melanoma 16. Urinary/bladder 17. Sarcoma 18. Pancreas 19. Head and neck 20. Ovary 21. Gastroesophageal 22.Mesothelioma 23.Endometrium | 1. 2 2. 10 3. 6 4. 8 5. 6 6. 5 7. 7 8. 10 9. 10 10. 9 11. 8 12. 8 13. 6 14. 5 15. 5 16. 10 17. 13 18. 7 19. 10 20. 14 21. 12 22. 7 23. 6 | 1. 1.000 2. 1.000 3. 1.000 4. 1.000 5. 1.000 6. 1.000 7. 1.000 8. 1.000 9 1.000 10. 0.889 11. 0.875 12. 0.875 13. 0.833 14. 0.800 15. 0.800 16. 0.800 17. 0.769 18. 0.714 19. 0.700 20. 0.643 21. 0.583 22. 0.571 23. 0.333 | 1. 0.995 2. 0.994 3. 1.000 4. 0.994 5. 1.000 6. 0.994 7. 1.000 8. 1.000 9. 1.000 10. 0.983 11. 0.989 12. 0.983 13. 0.994 14. 0.983 15. 0.994 16. 0.971 17. 1.000 18. 0.994 19. 1.000 20. 0.976 21. 0.988 22. 1.000 23. 0.994
miRview mets Mueller, 2011^45^ 2008 Germany Fair | Age: NR Female: NR N: 89 | 1. Billary tract 2. Breast 3. Head and neck 4. Kidney 5. Liver 6. Lung 7. Melanocyte 8. Ovary 9. Stomach or esophagus 10. Thyroid 11. Colon 12. Prostate | 1. 1 2.18 3. 4 4. 17 5. 1 6. 16 7. 17 8. 5 9. 4. 10. 2 11. 4 12. 12 | 1. 0.000 2. 0.722 3. 1.000 4. 0.941 5. 1.000 6. 0.875 7. 1.000 8. 0.600 9. 1.000 10. 0.000 11. 0.750 12. 3/12 | 1. 1.00 2. 0.958 3. 0.894 4. 0.986 5. 1.00 6. 0.781 7. 0.903 8. 0.976 9. 0.988 10. 0.977 11. 0.953 12. NR
miRview mets Rosenfeld, 2008^34^ NR Multinational, not U.S. Good | Age: NR Female: NR N: 253 | 1. Bladder 2. Brain 3. Breast 4. Colon 5. Endometrium 6. Head and neck 7. Kidney 8. Liver 9. Lung 10. Lung pleura 11. Lymph node 12. Melanocytes 13. Meninges 14. Ovary 15. Pancreas 16. Prostate 17. Sarcoma 18. Stomach 19. Stromal 20. Testis 21. Thymus 22. Thyroid | 1. 2 2. 5 3. 5 4. 5 5. 3 6. 8 7. 5 8. 2 9. 5 10. 2 11. 5 12. 5 13. 3 14. 4 15. 2 16. 2 17. 5 18. 7 19. 2 20. 1 21. 2 22. 3 | Decision Tree 1. 0.00 2. 1.00 3. 0.60 4. 0.40 5. 0.00 6. 1.00 7. 1.00 8. 1.00 9. 0.80 10. 0.50 11. 0.60 12. 60 13. 1.00 14. 0.75 15. 0.50 16. 1.00 17. 0.40 18. 0.71 19. 1.00 20. 1.00 21. 1.00 22. 1.00 | Decision Tree 1. 1.00 2. 1.00 3. 0.97 4. 0.99 5. 0.99 6. 0.99 7. 0.99 8. 0.99 9. 0.95 10. 0.99 11. 1.00 12. 0.97 13. 0.99 14. 0.97 15. 1.00 16. 1.00 17. 0.99 18. 0.96 19. 1.00 20. 1000 21. 0.98 22. 1.00
miRview mets Rosenwald, 2010^35^ NR Multinational, U.S. Good | Age: NR Female: NR N: 204 | Validation 1. Biliary tract 2. Brain 3. Breast 4. Colon 5. Esophagus 6. Head and neck 7. Kidney 8. Liver 9. Lung 10. Melanoma 11. Ovary 12. Pancreas 13. Prostate 14. Stomach or esophagus 15. Testis 16. Thymus 17. Thyroid | Validation only 1. 7 2. 11 3. 38 4. 9 5. 1 6. 3 7. 10 8. 8 9. 26 10. 7 11. 13 12. 6 13. 20 14. 7 15. 8 16. 6 17. 24 | (1 or 2 predictions) 1.0.667 2. 1.00 3. 0.667 4. 0.889 5. 1.00 6. 1.00 7. 0.875 8. 1.00 9. 0.913 10. 0.857 11. 0.846 12. 0.50 13. 0.895 14. 0.40 15. 1.00 16. 0.833 17. 1.00 | (1 or 2 predictions) 1. 0.94 2. 1.00 3. 0.936 4. 0.944 5. 0.984 6. 0.924 7. 0.994 8. 0.994 9. 0.849 10. 0.978 11. 1.00 12. 0.978 13. 0.994 14. 0.989 15. 1.00 16. 0.978 17. 0.982
PathworkDx Beck, 2011^39^ NR U.S. only Good | Age: NR Female: NR N: 42 | 1. Bladder 2. Breast 3. Colon 4. Gastric 5. Hepatocellular 6. High grade sarcoma 7. Melanoma 8. Ovarian 9. Pancreas 10. Prostrate 11. Renal 12. Thyroid 13. Lung 14. Synovial sarcoma 15. Endometrial | 1. 1 2. 1 3. 5 4. 2 5. 2 6. 2 7. 2 8. 9 9. 2 10. 2 11. 6 12. 2 13. 2 14. 1 15. 2 | 1. 1/1 2. 1/1 3. 5/5 4. 0/2 5. 1/2 6. 2/2 7. 2/2 8. 6/8 9. 1/2 10. 2/2 11. 6/6 12. 1/1 13. 0/2 14. 0/1 15. 0/2
PathworkDx Grenert, 2011^40^ 2000–2007 U.S. only Good | Age: Range 22–74 Median 55 Female: 20 N: 37 | 1. Bladder 2. Breast 3. Colorectal 4. Gastric 5.Testicular gem cell 6. Kidney 7. Hepatocellular 8. Nonsmall cell lung 9. Non-Hodgkin’s lymphoma 10. Melanoma 11. Ovarian 12. Pancreas 13. Prostate 14. Sarcoma 15. Thyroid | 1. 3 2. 2 3. 3 4. 2 5. 3 6. 4 7. 3 8. 2 9. 3 10. 2 11. 3 12. 2 13. 1 14. 3 15. 1 | 1. 3/3 2. 2/2 3. 3/3 4. 2/2 5. 2/3 6. 4/4 7. 3/3 8. 2/2 9. 3/3 10. 2/2 11. 2/3 12. 2/2 13. 1/1 14. 3/3 15. 1/1 | NR
PathworkDx Monzon, 2009^44^ NR Multinational, U.S. Good | Age: <50: 142 50–59: 133 60–69: 139 ≥70: 132 Female: 290 N: 547 | 1. Bladder 2. Breast 3. Colorectal 4. Gastric 5. Germ cell 6. Hepatocellular 7. Kidney 8. Melanoma 9. Non-Hodgkin’s lymphoma 10. Nonsmall cell lung 11. Ovarian 12. Pancreas 13. Prostate 14. Soft tissue sarcoma 15. Thyroid | 1. 28 2. 68 3. 56 4. 25 5. 30 6. 25 7. 39 8. 26 9. 33 10. 31 11. 69 12. 25 13. 26 14. 31 15. 35 | 1. 22/28; 0.78 (0.590–0.917) 2. 64/68; 0.941 (0.856–0.984) 3. 52/56; 0.929 (0.82.7–0.98.0) 4. 18/25; 0.720 (0.506–0.87.9) 5. 22/30; 0.733 (0.541–0.877) 6. 23/25; 0.920 (0.740–0.990) 7. 37/39; 0.949 (0.827–0.994) 8. 21/26; 0.808 (0.606–0.93.4) 9. 31/33; 0.939 (0.708–0.993) 10. 27/31; .0871 (0.702–0.964) 11. 64/69; 0.928 (0.839–0.976) 12. 18/25; 0.720 (0.506–0.879) 13. 23/26; 0.885 (0.698–0.976) 14. 26/31; 0.839 (0.663–0.945) 15. 32/35; 0.914 (0.769–0.982) | 1. 519/519; 1.000 (0.993–1.000) 2. 471/479; 0.983 (0.967–0.993) 3. 487/491; 0.992 (0.979–0.999) 4. 519/522; 0.994 (0.983–0.999) 5. 517/517; 1.000 (0.993–1.000) 6. 521/522; 0.998 (0.998–1.000) 7. 507/508; 0.998 (0.989–1.000) 8. 520/521; 0.998 (0.989–1.000) 9. 511/514; 0.994 (0.983–0.999) 10. 509/516; 0.986 (0.972–0.995) 11. 473/478; 0.990 (0.976–0.9970) 12. 521/522; 0.998 (0.989–1.000) 13. 521/521; 1.000 (0.993–1.000) 14. 513/516; 0.994 (0.983–0.999) 15. 510/512; 0.996 (0.986–0.999)
PathworkDx Pillai, 2011^33^ NR U.S. only Good | Age: 10–20: 1 20–30: 19 30–40: 44 40–50: 79 50–60: 133 60–70: 104 70–80 : 63 ≥80: 14 Female: 257 N: 462 | 1. Bladder 2. Breast 3. Colorectal 4. Gastric 5. Hepatocellular 6. Kidney 7. Melanoma 8. Non-Hodgkin’s lymphoma 9. Nonsmall cell lung 10. Ovarian 11. Pancreas 12. Prostate 13. Sarcoma 14. Testicular germ cell 15. Thyroid | 1. 29 2. 57 3. 36 4. 25 5. 25 6. 28 7. 25 8. 29 9. 27 10. 45 11. 28 12. 25 13. 27 14. 25 15. 31 | 1. 23/29; 0.793 (0.603–0.920) 2. 55/57; 0.965 (0.879–0.996) 3. 33/36; 0.917 (0.775–0.982) 4. 18/25; 0.720 (0.506–0879) 5. 24/25; 0.960 (0.796–0.999) 6. 25/28; 0.893 (0.718–0.977) 7. 21/25; 0.840 (0.639–0.955) 8. 26/29; 0.897 (0.726–0.978) 9. 23/27; 0.852 (0.663–0.958) 10. 40/45; 0.889 (0.759–0.963) 11. 24/28; 0.857 (0.637–0.960) 12. 24/25; 0.960 (0.796–0.990) 13. 24/27; 0.889 (0.708–0.976) 14. 21/25; 0.840 (0.639–0.955) 15. 28/31; 0.903 (0.742–0.980) | NR
PathworkDx Stancel, 2011^46^ NR U.S. only Good | Age: NR Female: NR N: 20 | 1. Lung 2. Lymphoma 3. Colon 4. Pancreas 5. Breast 6. Ovarian 7. Gastric | 1. 4 2. 2 3. 1 4. 1 5. 4 6. 5 7. 2 | 1. 3/4 2. 2/2 3. 0/1 4. 1/1 5. 3/4 6. 5/5 7. 1/2 | NR
PathworkDx Wu 2010^48^ NR U.S. only Good | Age: Median: 41 Range: 21–56 Female: 3 N: 15 | 1. Lung 2. Breast 3. Melanoma 4. Lymphoma 5. Sarcoma 6. Colon 7. Head and neck 8. Gastric 9. Kidney | 1. 2 2. 3 3. 2 4. 3 5. 1 6. 1 7. 1 8. 1 9. 1 | 1. 1/2 2. 3/3 3. 2/2 4. 3/3 5. 1/1 6. 1/1 7. 0/1 8. 1/1 9. −/1 (failed QC) | NR
Pathwork Tissue of Origin Endometrial Test Lal, 2012^31^ NR U.S. only | Age, n of subjects in age range 30–50: 9 50–60: 24 60–70: 28 70–90: 14 Female: NR N: 75 | 1. Ovarian 2. Endometrial | 1. 30 2. 45 | 1. 42/45; 0.967 (0.817–0.986) 2. 29/30; 0.933 (0.828–0.999) | NR

Abbreviations: GIST = gastrointestinal stromal tumor; n = number; N = number; NR = not reported; TOO = tissue of origin; U.S. = United States.

Given the consistency of the accuracy rates across the studies and overlapping confidence intervals, we did a meta-analysis using a fixed effects model to estimate a summary measure of accuracy (Table 10). We did not use any covariates to adjust for heterogeneity. The meta-analytic summarized estimate across the studies was 85 percent (95% CI, 83% to 86%).

### miRview

#### Accuracy

The TOO call in miRview is based on the union of the calls made by the decision tree and the KNN.34 Four studies32, 34, 35, 45 reported on the accuracy of miRview in identifying the primary site in a tissue of known origin. Rosenfeld et al.,34 rated good, reported on the results of a validation study on a test set of 83 specimens. The reported accuracy was 86 percent (95% CI, not reported). Rosenwald et al.,35 rated good, reported on the results of a validation test on a sample of 188 cancers of known origin. In 159 cases (85%) either the decision tree or the KNN identified the TOO. This would suggest an overall accuracy of 85 percent. In addition, they reported that in 124 (66%) of the samples the two classification algorithms agreed. The accuracy in this group was 90 percent. The specificity in this group was reported to be over 99 percent. Mueller et al.,45 rated fair, assessed the accuracy of the test in 101 cases of brain and central nervous system (CNS) metastases of known origin and 54 cases of brain and CNS metastases originally classified as CUP. They reported an overall accuracy of 84 percent. This estimate leaves out all 12 cases of prostate cancer, 9 of which were classified incorrectly. The authors suggest that published evidence suggests that the miRNA profiles of primary prostate tumors differ significantly from the metastatic tumors, especially in the presence of antiandrogenic therapy. They further justify the exclusion by the fact that prostate cancers form only 2 percent of CUP cases. The reported specificity for these cases was 95 percent. Figure 5 displays the accuracy rate across the four studies for this test. In a study graded good, Meiri et al.32 reported an overall accuracy rate of 85 percent in 489 tissues of known origin, out of a sample of 509 tissues, that were assayed successfully. The sample included 149 metastatic cancers. For 403 samples of these 489 tissues, miRview predicted a single site of origin with an accuracy rate of 90 percent. The specificity was above 99 percent.

Figure 5 Point estimates and 95% confidence intervals for all the reviewed studies estimating accuracy in known tissue for miRview TOO

Figure 5 has the proportion of known tissue that were accurately identified by miReview in the four studies reviewed for KQ3a. The X axis has the authors and year of the studies; the y-axis has the accuracy estimates.

Given the consistency of the accuracy rates across the studies and overlapping confidence intervals, we did a meta-analysis using a fixed effects model to estimate a summary measure of accuracy (Table 11). We did not use any covariates to adjust for heterogeneity. The meta-analytic summarized estimate across the studies was 85 percent (95% CI, 83% to 87%).

### PathworkDx

Ten studies assessed the accuracy of the PathworkDx test in samples of known primaries. Dumur et al.,30 rated good, evaluated the accuracy of the test in tumors of known origin using 60 samples of archived snap-frozen tissue. They reported an overall accuracy rate of 87 percent. The confidence intervals were not reported. Among the 52 tissues that met all the quality assurance (QA) criteria for the test, the overall accuracy was 93.8 percent. Monzon et al.,44 rated good, reported on a prospective validation study that assessed the accuracy of the test on 547 samples of known origin. They reported an overall accuracy of 87.8 percent (95% CI, 85% to 90%) and specificity of 99.4 percent (95% CI, 98.3% to 99.9%). Pillai et al.,33 rated good, assessed the accuracy of the test on 462 FFPE tissue of known origin. They reported an overall accuracy rate of 89 percent (95% CI, 85% to 91%). Grenert et al.,40 rated good, also assessed the accuracy of the TOO test on 44 FFPE samples of known origin. They reported an overall accuracy of 95 percent (95% CI, 82% to 99%) and an overall specificity of 99.6 percent. Beck et al.,39 rated good, reported on the accuracy of 42 samples of tissues of known origin. Twenty-nine samples were tissues and morphologies included in the panel. The accuracy of the test in these tissues was 90 percent (95% CI, 73% to 97%). The accuracy for the 10 tissues with uncommon morphologies was significantly lower, 30 percent. Stancel et al.,46 in a study rated good, reported on the accuracy of the TOO test using body fluid specimens from 19 patients with metastatic cancer. The estimated accuracy was 78 percent. This study also had 9 samples from patients with benign conditions. Seven of these tissues were diagnosed as lymphomas by the TOO test. In a study rated good, Wu et al.48 assessed the accuracy of the test in 14 tissues of metastatic brain cancer of known origin. They reported an accuracy of 86 percent. In a study graded good, Kulkarni et al.43 compared the performance of PathworkDx TOO in detecting the tissue of origin to IHC in a sample of 10 tissues of known origin. They reported an accuracy rate of 90 percent for the PathworkDx TOO. In a study graded fair, Dumur et al.29 reported an accuracy rate of 97 percent (95% CI, 80% to 100%). The sample for the study included 29 tissues of known origin. Initially it appeared that the TOO test agreed with only 23 of the 29 known tissue calls. However, an examination of the 6 discordant cases revealed that the PathworkDx TOO call was accurate and the tumor site predicted by the TOO test was later confirmed by imaging or IHC tests.

Figure 6 has the accuracy rates for the nine studies for this test. Given the consistency of the accuracy rates and overlapping confidence intervals across the studies, we did a meta-analysis using a fixed effects model to estimate a summary measure of accuracy. The meta-analytic summarized accuracy rate for PathworkDx is 88 percent (95% CI, 86% to 89%).

Figure 6 Point estimates and 95% confidence intervals for all the reviewed studies estimating accuracy in known tissue for PathworkDx TOO

Figure 6 has the proportion of known tissue that were accurately identified by Pathworks in the nine studies reviewed for KQ3a. The X axis has the authors and year of the studies; the y-axis has the accuracy estimates.

#### Pathwork Endometrial

One study, graded good, assessed the quality of the Pathwork Endometrial Test. Lal et al.31 reported findings of a study designed to estimate the accuracy of the Pathwork Endometrial Test to distinguish between endometrial and ovarian sites of origin. In a sample of 45 endometrial cancer tissues and 30 ovarian cancer tissues, they reported an accuracy rate of 97 percent for ovarian cancers and 93 percent for endometrial cancers. They also reported an area under the curve for the test, which measures the ability of the test to discriminate between endometrial and ovarian cancers, of 0.997.

## Key Question 4 How successful are TOO tests in identifying the TOO in CUP patients?

Eighteen studies,14, 24, 29, 36, 39, 45, 50–61 eight14, 29, 36, 50–52, 54, 60 rated good and ten24, 39, 45, 53, 55–59, 61 rated fair provided evidence on this question. We assessed the clinical utility of TOO tests by evaluating the evidence that they accurately identify the tumor TOO and that the test results contributed to the final clinical diagnosis. The evidence is summarized in Table 12.

PathworkDx TOO and CancerTypeID had multiple studies from which the data might have been summarized with a meta-analysis. However, the comparison diagnosis used as a gold standard was inconsistent and incomparable across studies. We therefore decided against creating a summary estimate.

Table 12 Success of TOO tests in identifying the TOO in CUP patients

TOO Test, Author, Year Study Dates, Region, Quality Rating | Sample Characteristics | TOO Predicted Result (confirmed) | Indeterminate Results | Number of Clinically Useful Cases
CancerTypeID Erlander, 2011^24^ NR Multinational, U.S. Fair | Age: Mean( ± SD): 62 (13) ≥65: 44% Female: 53% N: 300 | 296 (Consistent with clinicopathologic impressions: 139 [47%]) | 4 | Confirmed single suspected dx: 43/55 (78%) Confirmed one of multiple differential dx: 99/131 (74%) Provided additional information in cases of indeterminate origin: 37%
CancerTypeID Greco, 2010^51^ 2000–2007 U.S. only Good | Age: 25–50: 4 50–64: 8 65+: 8 Female: 11 N: 20 | 18 (15) | 2 | NR
CancerTypeID McGee, 2009^61^ 2009 US only Fair | Age: Mean: 64 ± 13 F: 40% N: 62 Clinician survey: 22 (20 responses) | 62 (15 of 20 with follow up) | | Guided or confirmed diagnosis: 10/20 Changed clinical diagnosis: 7/20
CancerTypeID Schroder, 201257 NR U.S. only Fair | Age: Median: 62 years Female: 51% N: 815 | 91% | | Pretest diagnosis unknown: CTID diagnosed 59 (93%) cases Differential diagnosis provided: CTID resolved dx in 55% cases. Provided new primary dx: 36%
CancerTypeID Thompson, 2011^58^ 2008–2011 U.S. only Fair | Age: NR Female: NR N: 171 | 144 (by latent primary: 18/24 (75%); by IHC or clinical features: 101/144 (70%)) | | Confirmed 1 of 2–3 IHC differential diagnoses: 43/97
G-banded karyotype (supplemented by FISH and comparative genomic hybridization Pantou, 2003^14^ 2001 Multinational, not U.S. Good | Age: <25: 1 25–50: 4 50–64: 4 65–older: 7 Mean age: 59.2 Female: 3 N: 20 | 5/20 identified cases 2/20 no mitoses 1/20 normal karyotype | NR | NR
miRview mets Mueller, 2011^45^ 2008 Germany Fair | Age: NR Female: NR N: 54 | 50 (40) 10 were discordant 4 origin never diagnosed | NR | NR
miRview mets^2^ Pavlidis, 2012^60^ NR NR Good | Age: NR Female: NR N: 92 | 84/92 (92%) | 8 | NR
miRview mets Varadhachary, 2011^36^ 2008–2010 U.S. only Good | Age: 58 Range: 20–83 Female: Total: 66 N: 87 | 74 (62) | NR | IHC not helpful: 9 TOO prediction: 9 TOO consistent with clinicopathological: 7
Pathwork Tissue of Origin Test Azueta, 2012^50^ 1992–2010 Spain Good | Age: NR Female: NR N: 32 | Total: TOO: 32 (25/29) IHC: 28 (20/29) Peritoneal: TOO: 7 (7) IHC: 5 (5) Ovarian: TOO: 18 (22) IHC: 15 (22) Unknown: TOO: 2 IHC: 2 | NR | NR
PathworkDx Beck, 2011^39^ NR U.S. only Fair | Age: NR Female: NS N: 7 | 4 (2 clearly incorrect) | 3^52^ | 2
Pathwork Tissue of Origin Test Dumur, 2011^29^ NR U.S. only Good | Age: Mean: 60 Range: 37–85 Female: 26 N: 40 | Overall: 29/40 (28); On panel: 28/29; Off panel: 4 discordant, 9 unreported | 3 inadequate sample: 1 indeterminate, 2 discordant. Off panel: 2 indeterminate | 29/40. Confirmed original diagnosis: 23 Changed diagnosis: 5 Excluded suspected diagnosis: 1 TOO results obtained “several months” before IHC and imaging results.
PathworkDx Hainsworth, 2011^52^ 2005 U.S. only Good | Age: Median: 56 Range: 21–86 Female: 21 N: 45 | 43 | 2 | NR
Pathwork Tissue of Origin Test Laouri, 2011^53^ 2009 U.S. only Fair | Age: Median: 62 years Range: 16–69 years Female: 57% N: 284 | Pretest diagnosis: Nonspecific: 172/183 Specific: 100/101 New diagnosis: 57(43) | Nonspecific: 12 | Total: New posttest diagnosis: 81% (95% CI:76–85%), Confirmed suspected diagnosis: 15% Pretest diagnosis: Nonspecific: Specific posttest diagnosis: 94% B. Specific: Confirmed diagnosis: 44% New diagnosis: 55%
PathworkDx Monzon 2010^54^ 2006 U.S. only Good | Age: 40–49: 1 50–59: 4 60–69: 6 70–79: 7 80–89: 3 Female: 15 N: 21 | 16 (10) 6 plausible | 5 | 16
PathworkDx Nystrom 2012^55^ NR U.S. only Fair | Physician: Ordered TOO test N: 65 (of 308 eligible) Patients: Age: Mean (SD): 64 (12) Female: 61 Race: White: 95 African American: 4 Hispanic: 4 Asian American: 2 Other: 2 N: 107 patients | NR | NR | Changed diagnosis: 54/107 Provide diagnosis for patients with no working diagnosis: 27/44 No change in tissue site diagnosis: 37/107 Physician found test clinically useful: 66%
PathworkDx Pollen, 2011^56^ 2009–2011 U.S. only Fair | Age: NR Female: NR N: 19 | 17 | 2 | Concurred with original diagnosis: 5 Changed diagnosis: 9/17 Changed diagnosis of primary tumor to metastatic: 2 (included in 9 above)

Abbreviations: CI = confidence interval; CTID =CancerTypeID; FISH = fluorescent in situ hybridization; IHC = immunohistochemistry; n = number; N = number; NR = not reported; SD = standard deviation; TOO = tissue of origin.

### CancerTypeID

Five studies,24, 51, 57, 58, 61 one51 rated good and four24, 57, 58, 61 rated fair examined the success and utility of CancerTypeID in diagnosing CUP patients. Among four studies, CancerTypeID test predicted a TOO in 84 percent58 to 99 percent24 of the cases. Two studies51, 58 included CUP cases for which the primary site was later identified. In both studies, the CancerTypeID diagnosis was confirmed in 75 percent of cases. Three studies24, 57, 61 compared the TOO prediction to the suspected or diagnosed TOO based on clinicopathologic characteristics. The assay results were consistent with the clinicopathologic characteristics in 47 percent of patients in the study by Erlander et al.,24 77 percent of patients in the study by McGee et al.,61 and 70 percent of patients in the study by Thompson et al.58 McGee et al.61 followed up with the referring physicians in 22 cases identified by CancerTypeID testing as squamous cell lung carcinoma. The final diagnosis was lung cancer in 15 of 20 cases with followup information. The assay results confirmed or guided the diagnosis in 10 cases and changed the diagnosis in 7 cases. In the study by Schroeder et al.,57 the CancerTypeID results provided a diagnosis in 93 percent of cases with no existing diagnosis and resolved 55 percent of cases with multiple differential diagnoses at the time of testing. In 36 percent of these cases, the assay diagnosis was not any of the differential origins.

#### Cytogenetic Analysis

One study14 reported on the ability of cytogenetic analysis to identify the TOO for tumors of unknown primary site. Five tumors (25%) had cytogenetic abnormalities that were diagnostic of a specific cancer type and primary site.

### miRview mets

One good study36 reported on the clinical utility of miRview mets TOO predictions among patients diagnosed with CUP. In the study by Varadachary36,from 104 patients enrolled, 87 tumor samples were sufficient for analysis; of these, 74 passed quality control and returned a result. The TOO results were consistent with the final diagnosis in 62 of 74 cases, or 71 percent of the 87 cases in which profiling was attempted. Sixty-five cases had differential diagnoses based on pathology and IHC results. The TOO assay was consistent with one of the differential diagnoses in 55 of these cases. Nine cases could not be classified by IHC or pathology. The miRview TOO results matched the clinical presentation for 7 of these cases.

Two studies45, 60 reported on the accuracy of miRview mets in diagnosing the TOO in CUP patients. Palvidis et al.,60 in a study rated good, reported on the results of TOO testing of metastatic tumors from 92 CUP patients. The test predicted a TOO in 84/92 patients, and the TOO was consistent with the final diagnosis in 92% of the cases. Mueller et al.,45 rated fair, reported on testing results in 54 CUP patients with brain or spinal metastases. The TOO test agreed with the best available data in 40 (74%) of these 54 cases. A clinically confirmed primary tumor was found for 28 patients. The TOO test had correctly predicted the origin in 22 of these cases. A diagnosis was suggested by pathology results but never clinically confirmed in 22 cases. The TOO results were consistent with pathology results in 18 of these 22 cases and inconsistent in 4 cases. Four cases had no suggested origin.

### PathworkDx

Eight studies29, 39, 50, 52–56 provided evidence on the utility of the PathworkDx test for diagnosis of CUP patients. Four studies29, 50, 52, 54 were rated as good, and four39, 53, 55, 56 as fair. The PathworkDx test predicted a TOO in 57 percent39 to 100 percent50 of samples from CUP patients. Three studies29, 50, 54 provided information on the agreement between the TOO results and the clinicopathologic characteristics or final diagnosis. Agreement ranged from 63 percent agreement with clinicopathologic characteristics54 to 97 percent agreement with the later identified primary location50 or the original or final diagnosis.29 Beck et al.39 reported on only seven CUP cases. Three cases had indeterminate results, and in two of the remaining four cases, the prediction was inconsistent with the clinical characteristics.

Six studies29, 39, 53–56 provided information on the agreement of the TOO results with the differential diagnoses prior to testing and the utility of the TOO assay results in determining the final diagnosis. In the study by Beck et al.,39 the TOO assay prediction matched one of the tumor types in the differential diagnoses in 2 of 4 cases with predictions. The authors commented that the test was probably clinically useful in these 2 CUP cases. In the study by Monzon et al.,54 the assay results were included in the differential diagnosis in 10 of 16 cases with predictions. In the other 6 cases, the authors felt the assay predictions were plausible and in some cases, the assay ruled out tissues in the differential diagnosis. They felt the results in all 16 cases contributed to the management of the cases. Laouri et al.53 reported on 284 cases, of whom 272 (96%) received a predicted TOO. The TOO test provided a new diagnosis in 94 percent (172 of 183) of cases without a specific diagnosis and in 44 percent (57 of 101) of cases that had a specific diagnosis prior to testing. Overall, 81 percent of cases had a new diagnosis after testing. Pollen et al.56 reported on 19 difficult to diagnose cases: The TOO assay changed the diagnosis in 9 of 17 cases (53%). In 2 of these cases, a tumor thought to be a primary tumor was determined to metastatic.

Nystrom et al.55 surveyed the referring oncologists to ask how the TOO assay results were used. They found that the assay changed the diagnosis in 53 percent of cases and provided a new diagnosis in 27 of 44 cases (61%) with no suspected diagnosis. The response rate for the survey was very low (21%), however.

## Key Question 4a What is the evidence that genetic TOO tests change treatment decisions?

The evidence regarding the effect of TOO tests on treatment decisions is very limited. Six studies55, 58, 62–64 reported on the effect of TOO tests on treatment decisions. One study64 was rated as good, but it was available only as a poster. Table 13 displays the results.

Three studies55, 59, 61 examined the effect or potential effect of TOO results on patient management decisions. Laouri et al.59 examined the TOO test results in 284 cases and compared the National Comprehensive Cancer Network (NCCN) treatment recommendations between the pre-test diagnosis and the diagnosis based on the PathworkDx TOO assay. They found that the treatment recommendations changed in 81 percent of the cases. For 178 cases, the chemotherapy regimen recommended by the NCCN guidelines was completely different after the test results. Nystrom et al.55 surveyed physicians who had ordered a PathworkDx test about their use of the test results. Among the physicians who responded, two-thirds felt the test was clinically useful, and the test resulted in a change in the management of 65 percent of the patients.

Table 13 Evidence of genetic TOO tests changing treatment decisions

TOO Test, Author, Year Study Dates, Region, Quality Rating | Sample Charac- teristics | Cancer/ Tumor Types | Number Eligible | Participated/ Response | Eligibility Criteria | Indicated TOO | Treatment and Response | Treatment Change | p-value TOO vs. CUP Treatment
CancerTypeID Greco, 2012^62^ NR U.S. only Fair | Age: Median: 61 years Range: 46–81 years Female: 18 N: 32 | CUP | 32 | 32 | Colorectal gene expression signature | Colorectal cancer | First-line: Folfox/Folfiri 19 Other colorectal cancer drug: 4 Empiric: 8 (6/8 received CRC treatment for second-line) First-line CRC treatment: 17/23 (74%) Second-line CRC: 7/13 (54%) Any first-line treatment: 22/32 (69%) Any second-line treatment 7/13 (54%) | Not applicable: retrospective study
CancerTypeID Hainsworth, 2010^64^ NR NR Good | Age: Median: 64 Range: 26–85 Female: 33 N: 110 | CUP | 110 | Received assay-directed treatment: 66 Evaluated: 51 | Not a treatable subset of CUP No previous systematic treatment ECOG performance status 0–2 No uncontrolled brain metastases | Pancreatic: 11 Colorectal: 8 Urinary/bladder: 8 Nonsmall cell lung: 5 Ovarian: 4 Carcinoid - intestine: 4 Breast: 3 Gallbladder: 3 Liver: 3 Renal cell: 3 Skin (squamous): 3 Other: 7 No specific diagnosis: 5 | Assay-directed treatment Objective treatment response: 21/51 (41%) | Changed: 66 (60%) Not changed: 44 (40%)
CancerTypeID Hainsworth, 2011^63^ 3/2008–8/2009 NR Fair | Age: Median: 57 Range: 35–86 Female: 27 N: 125 | CUP or other identified as colorectal by TOO test | 125 | 42 (34%) | NR | Identified by TOO test with ≥80% probability as colorectal adenocarcinoma | First-line: Advanced colorectal cancer: 12/24 Empirical for CUP: 17% (Total: 18) Second line: CRC: 8/16 | Changed: 32 Not changed: NR | p=0.0257
CancerTypeID McGee 61 2009 US only Fair | Age: Mean: 64 ± 13 F: 40% N: 22 | Squamous cell lung carcinoma | 22 | 20 | Squamous cell lung carcinoma profile by CancerTypeID | Squamous cell lung carcinoma | Lung cancer therapy: 15/20 Head and neck cancer therapy: 2/20 Colorectal cancer therapy: 1.20 Unknown/ missing: 2 | NR | NR
CancerTypeID Thompson, 2011^58^ 2008–2011 U.S. Only Fair | Age: NR Female: NR N: 21 | CUP with colorectal TOO result | NR | NR | NR | Colorectal cancer | Response: 70%
PathworkDx Laouri, 2010^59^ 2009 NR Fair | Age: Median: 62 Range: 16–89 Female: 161 N: 284 Nonspecific diagnosis: 183 Specific diagnosis: 101 | Liver, lymph node, omentum and peritoneum, lung, soft tissue, bone, neck, brain, ovary, colon and rectum, pleura, pelvis, small bowel, other | NR | 284 | NR | TOO predicted: 221 (78%) Colorectal (15%) Breast (15%) Ovary (13%) Pancreas (13%) Nonsmall cell lung (11%) Hepatocellular (11%) Sarcoma, kidney, gastric, other (78%) | Change in first-line therapy: Initial nonspecific primary site: 135 major, 37 minor, 11 none Specific primary site: 43 major; 14 minor; 44 none Treatment response: NR | Changed: 229 (81%) Not changed: 55 (19%) | NR
PathworkDx Nystrom, 2012^55^ NR U.S. only Fair | Age: Mean (SD): 64 (12) Female: 61 N: 316 physicians | Lymph node, soft tissue, liver, lung, bone, brain | 316 physicians | 65 physicians 107 patients | Survey | | | Did not change treatment: 17 Any change: 70/107 (65%, 95% CI: 58%-73%) Chemotherapy changed: 58/107 (54%, 95% CI:46%–62%) Radiation therapy: 27/107 (25%) Increase in consistency with guidelines: 23%

Abbreviations: CI = confidence interval; CUP = cancer of unknown primary; ECOG = Eastern Cooperative Oncology Group; N = number; NR = not reported; SD = standard deviation; TOO = tissue of origin; U.S. = United States; vs. = versus.

Only 21 percent of surveyed physicians responded to the survey, however. McGee et al.61 surveyed referring physicians in 22 cases identified by CancerTypeID testing as squamous cell lung carcinoma. Patients received therapy consistent with a lung cancer diagnosis in 13 cases with a final diagnosis of lung cancer.

Three studies58, 62, 63 examined treatment decisions and response to treatment among cases that had a colorectal cancer gene expression profile. Hainsworth63 found that 32 of 42 patients received first-line (24) or second-line (8) colorectal cancer treatment based on CancerTypeID results. Treatment response was much higher among patients treated with colorectal cancer specific therapy (20 of 40, 50%) than among patients who received empirical treatment for CUP (3 of 18, 17%). In the study by Greco et al.,62 17 of 23 (74%) of patients who received first-line colorectal cancer treatment responded to treatment. Among patients who received any first-line treatment, 22 of 32 (69%) responded to treatment. Thompson et al.58 reported that 70 percent of patients in their study who received colorectal chemotherapy responded to treatment.

In another study, Hainsworth et al. presented preliminary results from a clinical trial that assigned treatment based on CancerTypeID results.64 Of 110 enrolled patients, 66 received assay-directed treatment. The response to treatment was evaluated for 51 patients who received assay-directed treatment, and 21 (41%) responded to treatment.

## Key Question 4b What is the evidence that genetic TOO tests change outcomes?

The evidence for this response was limited. Seven studies,14, 26, 55, 58, 62, 63, 65 one14 rated as good and six26, 55, 58, 62, 63, 65 rated fair provided evidence on this question. Table 14 has the evidence for this question.

### CancerTypeID

Four studies58, 62, 63, 65 looked at the effect of the identification of the TOO on patient outcomes. In a study graded fair, Hainsworth et al.63 looked at the effect of TOO identification on treatment and patient outcomes. The report is based on the response to a survey that requested a response on 125 patients who had had an initial diagnosis of CUP and had the TOO identified as the colorectum. Of 125 surveys, 42 were returned. Thirty-two of these patients had received site-specific treatment for advanced colon cancer. Patients who were treated with site-specific regimens had a median survival of 8.5 months compared with 6 months in patients with empiric CUP therapy (p=0.11). In a second study graded fair, Hainsworth et al.65 reported on a prospective trial that tested CUP patients and treated the patient based on the test. A total of 194 patients were treated with site-specific therapy. The median survival among these patients was 12.5 months, 95% CI (9.1 to 15.4 months) compared with 10.8 months in patients who received empiric therapy. Greco et al.,62 in a study graded fair, reported on the results of a study of 32 patients for whom the TOO test indicated colorectal carcinoma as the primary cancer; 11patients were diagnosed between 2004 and 2007 at M.D. Anderson Cancer Center in Houston, Texas, using a TOO test called Veridex. The remaining 21 patients were diagnosed at the Sarah Cannon Research Institute in Nashville, Tennessee, with CancerTypeID between 2008 and 2010. The authors reported that the definitions used for CUP in both cohorts were the same. Twenty-nine of the 32 patients were treated with either first- or second-line colorectal cancer therapy. There is no detail about how many of these were from the first cohort and how many from the second. The median survival for all 32 patients was 21 months. The median survival for the 29 patients who had first- or second-line therapy was 22 months. The median survival of the 23 patients who received first-line colorectal cancer therapy was also 22 months. The authors reported that the historical data suggest that median survival for CUP patients treated with empiric therapy was about 9 months. Two-year and 4-year survival for the 32 patients was, respectively, 42 percent and 35 percent. In a study graded fair, Thompson et al.,58 reported a median survival of 21 months and a 70 percent response rate in patients who were treated with site-specific therapy for colon cancer.

Table 14 Evidence that genetic TOO tests change outcomes

TOO Test, Author, Year Study Dates, Region, Quality Rating | Sample Characteristics | Cancer/ Tumor Types | Number Eligible | Number Participated | Sample Requirements | Similarity Score | Indicated TOO | Outcome | Outcome by Group | Control
CancerTypeID Greco, 2012^62^ NR U.S. only Fair | Age: Median: 61 years Range: 46–81 years Female: 18 | CUP | 32 CTID: 21 Veridex: 11 | 32 | As marketed | NR | Colorectal cancer based on CTID or Veridex | Median survival: 2-year survival: 4-year survival: | Total sample: 21 months (95% CI: 17.1–24.9) First-line or second-line CRC treatment: (29 patients) 22 months First-line CRC treatment: 22 months Total sample: 42% Total sample: 35% | No control group
CancerTypeID Hainsworth, 2012^65^ 2008–2011 U.S. only Fair | Age: Median: 64 Range: 26–89 Female: 136 N: 223 | CUP | 223 historic controls | Empiric CUP therapy: 29 Site-specific therapy: 194 | NR | NR | Biliary tract, urothelium, colorectal, lung, pancreas, breast, ovary, gastroesophageal, kidney, liver, sarcoma, cervix, neuroendocrine, prostate, germ cell, skin, intestine, mesothelioma, thyroid, endometrium, melanoma, lymphoma, head and neck, adrenal | Median survival | TOO: 12.5 months (95% CI: 9.1–15.4) | Historical control: 9.1 months
CancerTypeID Hainsworth, 2011^63^ 3/2008–8/2009 NR Fair | Age: NR Female: NS N: 125 | CUP or other Identified by TOO as colo-rectal adeno-carcinoma | 125 | 42 (34%) | As marketed | | Identified by TOO test with ≥80% probability as colo-rectal adeno-carcinoma | Survival | TOO: 8.5 months p-value TOO vs. CUP: 0.11 | Control: Empirical treatment: 6 months
CancerTypeID Thompson, 2011^58^ 2008–2011 U.S. Only Fair | Age: NR Female: NR N: 21 | CUP with colorectal TOO result | | NR | NR | | Colorectal cancer | Median survival | 21 months | No control group
G-banded karyotype (supplemented by FISH and comparative genomic hybridization Pantou, 2003^14^ 2001 Multinational, not U.S. Good | Age: < 25: 1 25–50: 4 50–64: 4 65–older: 7 Mean age: 59.2 Female: 3 N: 20 | 5/20 identified cases 2/20 no mitoses 1/20 normal karyotype | NR | NR | | | | Median survival | Simple chromosomal changes: 19.7 months Complex changes: 3 months | No control group
PathworkDx Hornberger, 2012^26^ NR NR Fair | Patients: Age: Mean: 64 (SD:12) Female: 61 Race: White: 95 African American: 4 Hispanic: 4 Asian American: 2 Other: 2 N (patients): 107 | Any | 308 treating physicians who ordered TOO test | 65 (21%) | As marketed | | Any | Overall survival: projected increase, 15.9–19.5 months Average estimated increase in survival adjusted for QOL: 2.7 months | | No control group
Nystrom, 2012^55^ NR U.S. Fair | Patients: Age: Mean: 64 (SD:12) Female: 61 Race: White: 95 African American: 4 Hispanic: 4 Asian American: 2 Other: 2 N (patients): 107 | CUP | | | | | | Survival 14 months 95% CI (10.2–18.6) 2-year survival 33% 3-year survival 30% | CRC (19%) Breast (14%) Sarcoma (14%) Lung (11%) Ovarian (11%) Pancreas (10%) | No control group

Abbreviations: CI = confidence interval; CRC = colorectal cancer; CTID = CancerTypeID; CUP = cancer of unknown primary; FISH = fluorescent in situ hybridization; N = number; NR = not reported; QOL = quality of life; SD = standard deviation; TOO = tissue of origin.

### miRview

There is no published evidence on the test changing outcomes in patients with CUP.

### PathworkDx

Two studies, both graded fair, provided evidence about the effect of the identification of the TOO using PathworkDx on patient outcomes. Nystrom et al.55 reported on a survey that was sent to 316 physicians who had ordered the PathworkDx TOO test. Sixty-five physicians (21%) responded to the survey, which gathered information on the effect of the test on decisions and patient outcomes. The reported median survival for patients who had the test ordered was 14 months from the time of the biopsy (95% CI, 10.2 to 18.6 months). Two-year survival was 33 percent and 3-year survival was 30 percent. The test is known to have changed the treatment decision in 65 percent of the patients but there is no information about the survival outcomes for the patients whose treatment changed. Hornberger et al.26 reported on the same 107 patients described in Nystrom et al.55 They reported that the projected benefit of site-specific therapy as a result of the TOO was an increase in survival from 15.9 months to 19.5 months. The observed benefit was a quality of life (QOL) adjusted increase in average survival of 2.7 months.

## Key Question 5 Is the TOO test relevant to the Medicare population?

Twenty-two studies14, 24, 29, 31, 33, 36, 40, 42, 44, 47–49, 51–55, 57, 62, 63, 65, 66 provided information on the age of the cases in their study (Table 15). All but one48 included patients age 65 years or older, the Medicare core population. All of the studies of tests applicable to both cancers that provided information on the sex of the cases included both male and female cases. The studies and the TOO test panels include cancers specific to women (breast, ovarian) and to men (prostate, testicular). Only two studies33, 49, 55 provided information on ethnicity. In both of these studies, the majority of the patients were Caucasian. Pillai et al. included 68 (15%) patients of Asian-American or Pacific Islander ancestry. One study49 was conducted in China, so the patient population would be expected to be predominantly Chinese.

Table 15 TOO tests relevant to the Medicare population

TOO Test, Author, Year Study Dates, Region Quality Rating | Sample Size | Age | Female | Ethnicity | Cancer Types
CancerTypeID Erlander, 2011^24^ NR Multinational, U.S. Good | 300 | Mean (SD): 62 (13) | 53% | NR | Adrenal, brain, breast, cervix, cholangiocarcinoma, endometrium, esophagus (squamous cell), gallbladder, gastroesophageal (adenocarcinoma), germ cell, GIST, head/neck, intestine, kidney (renal cell carcinoma), liver, lung, lymphoma, melanoma, meningioma, mesothelioma, neuroendocrine, ovary, pancreas, prostate, sarcoma, sex cord stromal tumor, skin, thymus, thyroid, urinary/bladder
CancerTypeID Greco, 2010^51^ 2000–2007 U.S. only Good | 20 | 25–50: 4 50–64: 8 >65: 8 | 11 | NR | CUP
CancerTypeID Greco, 2012^62^ NR U.S. only Fair | 32 | Median: 61 Range: 46–81 | 18 | NR | CUP
CancerTypeID Hainsworth, 2010^64^ NR NR Good | 110 | Median: 64 Range: 26–85 | 33 | NR | CUP
CancerTypeID Hainsworth, 2011^63^ 3/2008–8/2009 NR Fair | 125 | Median: 57 Range: 35–86 | 27 | NR | Liver, bone/bone marrow, lymph nodes, peritoneum, lungs, abdominal/ retroperitoneal nodes, uterus/ovary, adrenal glands
CancerTypeID Hainsworth, 2012^65^ 2008–2011 U.S. only Fair | 223 | Median: 64 Range: 26–89 | 136 | NR | CUP
CancerTypeID Kerr, 2012^42^ NR NR Good | 790 | <50: 203 50–64: 271 >64: 316 | 405 | NR | Metastatic tumors and moderately to poorly differentiated primary tumors of the following types: Adrenal, brain, breast, cervix adenocarcinoma, endometrium, gastroesophageal, germ cell, GIST, head-neck-salivary, intestine, kidney, liver, lung-adeno/large cell, lymphoma, melanoma, meningioma, mesothelioma, neuroendocrine, ovary, pancreaticobiliary, prostate, sarcoma, sex cord stromal tumor, skin basal cell, squamous, thymus, thyroid, urinary/bladder
CancerTypeID Schroder, 2012^57^ NR U.S. only Fair | 815 | Median: 62 years | 51% | NR | CUP
CancerTypeID Weiss, 2012^47^ NR U.S. Good | 123 | Mean (SD): 61.2 (14.4) years | 52% | NR | Metastatic
CancerTypeID Wu, 2012^49^ NS China Good | 184 | Age: | 94 | Chinese | Adrenal, breast, endometrium, gallbladder, gastroesophageal germ-cell, GIST, head and neck, intestine, kidney, liver, lung, lymphoma, melanoma, mesothelioma, neuroendocrine, ovary, pancreas, prostate, sarcoma, skin, thyroid, urinary/bladder
miRview Varadhachary, 2011^36^ 2010 U.S. only Good | 104 | Age: Range: 20–83 Median: 58 Female: | 66 | NR | Lymph nodes, liver, lung, bone, pelvic mass/adnexae, skin/subcutaneous, omentum/peritoneum, adrenal, other
Pathwork Tissue of Origin Test Dumur, 2011^29^ NR U.S. only Good | 40 | Mean: 60 Range: 37–85 | 26 | NR | CUP
PathworkDx Grenert, 2011^40^ 2000–2007 U.S. only Good | 37 | Range: 22–74 Median: 55 | 20 | NR | Bladder, breast, colorectal, gastric, testicular gem cell, kidney, hepatocellular, nonsmall cell lung, non-Hodgkin’s lymphoma, melanoma, ovarian, pancreas, prostate, sarcoma, thyroid
PathworkDx Hainsworth, 2011^52^ 2005 U.S. only Good | 45 | Median: 56 Range: 21–86 | 21 | NR | CUP
Pathwork Tissue of Origin Test Kulkarni, 2012^43^ 2007–2011 U.S. only | 10 | NR | 3 | NR | Metastatic tumors from clinically identified primary site not diagnosed by IHC alone
PathworkDx Laouri, 2011^53^ 2010 NR Fair | 284 | Median: 62 Range: 16–89 | 161 | NR | Liver, lymph node, omentum and peritoneum, lung, soft tissue, bone, neck, brain, ovary, colon and rectum, pleura, pelvis, small bowel, other
PathworkDx Monzon, 2009^44^ NR Multinational, U.S. Good | 547 | <50: 142 50–59: 133 60–69: 139 ≥70: 132 | 290 | | Colorectal, pancreatic, nonsmall cell lung, breast, gastric, kidney, hepatocellular, ovary, sarcoma, non-Hodgkin’s lymphoma, thyroid, prostate, melanoma, bladder, testicular germ cell
Monzon, 2010^54^ 2006 U.S. only Good | 21 | 40–49: 1 50–59: 4 60–69: 6 70–79: 7 80–89: 3 | 15 | NR | CUP
PathworkDx Nystrom, 2012^55^ NR U.S. only Fair | 107 | Mean (SD): 64 (12) | 61 | White: 95 African American: 4 Hispanic: 4 Asian American: 2 Other: 2 | CUP
PathworkDx Pillai, 2011^33^ NR U.S. only Good | 462 | 10–20: 1 20–30: 19 30–40: 44 40–50: 79 50–60: 133 60–70: 104 70–80: 63 ≥80: 14 | 257 | African American: 3 Asian/Pacific Islander: 68 European: 314 | Bladder, breast, colorectal, gastric, testicular germ cell, kidney, hepatocellular, nonsmall cell lung, non-Hodgkin’s lymphoma, melanoma, ovarian, pancreatic, prostate, thyroid, sarcoma
PathworkDx Wu, 2010^48^ NR U.S. only Good | 15 | Median: 41 Range: 21–56 | 3 | NR | Lung, breast, melanoma, lymphoma, sarcoma, colon, head and neck, gastric, kidney
Pathwork Tissue of Origin Endometrial Test Lal, 2012^31^ NR U.S. only Good | 75 | 30–50: 9 50–60: 24 60–70: 28 70–90: 14 | 75 | | Ovarian, endometrial
G-banded karyotype (supplemented by FISH and comparative genomic hybridization Pantou, 2003^14^ 2001 Multinational, not U.S. Good | 20 | <25: 1 25–50: 4 50–64: 4 65–older: 7 Mean: 59.2 | 3

Abbreviations: CI = confidence interval; CUP = cancer of unknown primary; FISH = fluorescent in situ hybridization; GIST = gastrointestinal stromal tumor; IHC = immunohistochemistry; N = number; NR = not reported; SD = standard deviation; TOO = tissue of origin.