# Methods

## Literature Search Strategies

The scope of the review was limited to tests that are commercially available in the United States. We identified genetic or molecular tissue-of-origin (TOO) tests by searching GeneTests.org, the NIH Genetic Testing Registry, the GAPP Knowledge Base, and the following the Food and Drug Administration databases; Premarket Notifications (510(k)), Premarket Approvals, and Clinical Laboratory Improvement Amendments databases. We also searched the Internet using the search strategy shown in Table 3. We defined a “commercially available” test as one for which an Internet search or test directory identified a mechanism for a physician or laboratory to order the test or to buy a kit to perform the test.

Table 3 Google search strategy for TOO tests

Search | Queries
#1 | “tissue of origin” OR “cancer of unknown” OR “tumors of unknown” laboratory test
#2 | Limited to pages in English, updated in last year

We included systematic reviews, randomized controlled trials, nonrandomized controlled trials, prospective and retrospective cohort studies, case-control studies, and case series published from 1990 to present. We excluded non-English studies; a preliminary search found very few studies published in other languages. The inclusion and exclusion are listed in Appendix A. We searched the grey literature for relevant studies but did not contact authors for additional data. We included conference presentations and posters when they presented data not published elsewhere.

We conducted targeted searches for unpublished or grey literature relevant to the review. We identified grey literature relevant to the key questions (KQs) through review of Lexus Nexus, the test developers’ Web sites, ClinicalTrials.gov, Health Services Research Projects in Progress, and the European Union Clinical Trials Register. We included studies that met all of the inclusion criteria and that contained enough information on the study methods to assess the risk of bias.

We systematically searched, reviewed, and analyzed the scientific evidence for each KQ. To identify articles for this review, we conducted focused searches of PubMed, Embase, and the Cochrane Library. The search was conducted in three stages. First, an experienced research librarian used a predefined list of search terms and medical subject headings (MeSH). The search terms and limits for PubMed are listed in Table 4, MESH Heading Search. We also reviewed the test manufacturers’ Web sites and the reference lists of identified papers and reviews for previously unidentified relevant papers. Following the review of the manufacturer’s Web sites, we conducted a second search of the databases using text words, shown in Table 4, Text Word Search. We limited the search to studies published in English based on limited resources; this may bias the report to include more studies from English-speaking countries. Complete search strategies are provided in Appendix B.

Table 4 Illustrative search strategies (PubMed)

Search | Queries | Number of Citations
MeSH Heading Search
#1 | Search Neoplasms, Unknown Primary[mh] | 2,398
#2 | Search (“Gene Expression Profiling”[MeSH]) OR “Microarray Analysis/methods”[Majr] | 64,521
#3 | Search #1 AND #2 | 38
#4 | Search Pathwork diagnostics OR Agendia OR CancerTypeID OR miRview mets test OR Rosetta Genomics OR AviaraDX OR Quest Diagnostics | 18,686
#5 | Search #1 AND #4 | 6
#6 | Search #3 OR #5 | 39
#7 | Search #3 OR #5 Limits: Humans, English, Publication Date from 2000 | 35
#8 | Search Neoplasms/genetics[mh] | 229,992
#9 | Search Neoplasms/classification[Majr] OR Neoplasms/diagnosis[Majr] | 607,681
#10 | Search #8 AND #9 | 39,811
#11 | Search (“Reproducibility of Results”[Mesh]) OR “Accuracy and Specificity”[Mesh] | 478,953
#12 | Search #10 AND #11 | 2,966
#13 | Search Oligonucleotide Array Sequence Analysis/methods[Majr] | 8,345
#14 | Search #12 AND #13 | 102
#15 | Search #12 AND #13 Limits: Humans, English, Publication Date from 2000 | 96
#16 | Search #10 AND #4 Limits: Humans, English, Publication Date from 2000 | 72
#17 | Search #3 OR #15 OR #16 Limits: Humans, English, Publication Date from 2000 | 195
Text Word Search
#1 | Search “tissue of origin” and “cancer” | 188
#2 | Search neoplasms, unknown primary | 6,765
#3 | Search neoplasms, unknown primary/genetics | 82
#4 | Search #1 OR #3 | 259
#5 | Search #1 OR #3 limits: humans, English | 219
#6 | Search #1 OR #3 limits: humans, English, publication date from 2000 | 157

We updated the literature review by repeating the initial searches and reviewing the publication list on the manufacturers’ Web sites concurrent with the peer review process. Any literature suggested by peer reviewers or public comment respondents was investigated and, if appropriate, incorporated into the final review. The review includes all identified literature published or e-published between January 1, 2000, and November 7, 2012.

## Study Eligibility Criteria

Two trained members of the research team independently reviewed all identified titles and abstracts for eligibility against our inclusion/exclusion criteria. Studies marked for possible inclusion by either reviewer underwent full-text review. For studies without adequate information to determine inclusion or exclusion, we retrieved the full text and then made the determination. Each article included in the full-text review was independently reviewed by two investigators. If both reviewers agreed that a study did not meet the eligibility criteria, the study was excluded. Conflicts were resolved by discussion and consensus. We recorded the reason each excluded full-text publication did not satisfy the eligibility criteria studies.

## Data Management

EndNote was used to organize and track retrieved citations.

## Data Abstraction

For each included study, data were abstracted into a standard abstraction table by an abstractor trained in genetics and epidemiology or biostatistics. A senior investigator reviewed each abstraction. The data abstraction form gathered information on the study populations, settings, interventions, comparators, study designs, methods, and results.

## Quality Assessment

We assessed the risk of bias in the reviewed studies using the criteria described in the Methods Guide for Medical Test Reviews.17 For studies of analytic or clinical validity (KQs 2 and 3), we considered the potential for bias due to flaws in the sample selection, testing protocol, reference standards, verification procedures, interpretation, and analysis. We used the QUADAS19 criteria to assess studies of diagnostic accuracy. For studies of clinical utility (KQ 4), we used questions from the RTI Question Bank20 to assess the potential for bias from sample selection, study performance, attrition, detection of outcomes, and reporting. Studies that included information on both analytic and clinical validity and on clinical utility received separate ratings for each domain, each based on the relevant assessment instrument.

Quality assessment results were summarized as good, fair, or poor, correlating with a low, medium, or high risk of bias. The ratings are defined in Appendix D.

A study was rated as good if it had a strong design, measured outcomes appropriately, used appropriate statistical and analytical methods, reported low attrition, and reported methods and outcomes clearly and precisely. As a result, the reviewers have a high degree of confidence that the reported results reflect minimal bias and that the reported effect or correlation is similar in direction and magnitude to the actual relationship. For studies to have been rated good, the source and selection criteria of the tumors or participants in the study had to be clearly explained with no obvious source of bias and the study had to include an appropriate comparison group. If the tumor origin was known, the interpretation of the TOO had to be made without knowledge of the tumor origin. The reported results had to account for all tumors or participants included in the study. A fair study does not meet all criteria of a good study, but its flaws are not likely to cause major bias in the results. The reviewers had a high degree of confidence that the reported relationship is in the same direction as the actual relationship but only moderate confidence that the reported relationship is of the reported magnitude.

Poor studies have at least one flaw in the study’s design, conduct, or analysis that could invalidate the results. We identified one study21 that was rated poor. Two senior investigators trained in epidemiology and statistics independently assessed the quality of each study. Disagreements between the two reviewers were resolved by discussion until consensus was reached.

## Data Synthesis

We summarized the evidence for each KQ in evidence tables.

### Meta-Analysis

Meta-analytic techniques were used to generate summary measures across studies when there were more than two studies using the same test that addressed the same KQ. For each test, three or more studies addressed KQ 3b, the ability of the tests to identify tests of known origin. Meta-analysis was used to estimate summary measures across these studies.

The CancerTypeID and PathworkDx TOO tests also had more than three studies that assessed the ability of the tests to detect the TOO in true CUP cases. Because the criteria for assessing the accuracy of the test varied widely across these studies and several of these criteria seemed inappropriate, we decided not to summarize the accuracy measures across these studies. The miRview mets test only had two studies that estimated the accuracy of the test in CUP patients.

As discussed above, for the tests described in this review the only appropriate summary measure is a single measure of accuracy. To determine whether summarizing the measure across the studies was appropriate, we assessed heterogeneity of accuracy estimates across studies by using forest plots to display the reported accuracy (correct identification of the TOO) for TOOs. Given the homogeneity of estimates across the studies, it was determined that the most appropriate way to combine the estimate across studies was to use a fixed effects model to estimate the population parameter that the estimates from the various studies represent.

Test performance is measured in terms of accuracy. In the studies of known tissue, accuracy is defined as the proportion of test results that agree with the known TOO. We used a univariate fixed-effects model for meta-analysis. The model in the ith study is

(1)

where β_fixed_ is the average effect under fixed-effects model and e_i_ is the error term. Variance of e_i_ is v_i_, which was estimated from the data. We used the “metaSEM” package available in “R” statistical language (R Development Core Team 2011) to perform meta-analysis using fixed-effects model.

### Grading the Evidence for Each Key Question

For KQs 2, 3b, and 4, we graded the overall strength of evidence according to the guidance established for the Evidence-based Practice Center Program.17, 22 This approach incorporates four key domains: risk of bias (including study design and aggregate quality), consistency, directness, and precision of the evidence. Grades reflect the strength of the body of evidence to answer the KQs on the validity and efficacy of the interventions in this review. We used Simon18 criteria to assess the validity of the development of statistical classification algorithms. We assessed four criteria: the validity of the normalization methods; the validity of the statistical classification method, in particular; whether the assessment was based on supervised or unsupervised classification; and the risk of bias in the validation methods. We rated the first three criteria as valid or invalid as follows: valid normalization method: normalized based on housekeeping genes or total expression levels; validity of the statistical methods: supervised classification. We graded the overall strength of evidence according to the guidance established for the Evidence-based Practice Center Program. Two senior reviewers assessed each domain and the overall grade for each key outcome listed in the framework. Conflicts were resolved by discussing until consensus was reached. For KQs 2 and 3, strength of evidence was graded for each test. The risk of bias was rated as low, moderate, or high. It was graded as low if the validation was conducted using a completely separate validation sample or using leave-one-out validation analysis. For KQ 4, the strength of evidence was graded for each outcome (e.g., treatment change, clinical outcomes).

### Assessing Applicability

KQ 5 evaluates the applicability of the genetic TOO tests to the core Medicare populations (i.e., individuals 65 years and older) in terms of patient age, race, and primary diagnosis. We assessed KQ 5 by considering the characteristics of the sample for the studies and compared them with the core Medicare population.