# Introduction

## Background and Objectives for the Systematic Review

### A Brief Overview of Cancer

Cancer is one of the leading causes of death in the United States. The National Cancer Institute (NCI) estimates 1,596,670 new cases of cancer, excluding melanomas, will be diagnosed in 2011.^1^ Over half a million deaths in 2011 were expected to be attributed to cancer.

Cancer begins when the normal processes of cell division and death get interrupted and cells in a part of the body begin to grow uncontrollably. The abnormal cells multiply and interrupt normal function of the tissue. Hanahan and Weinberg2 suggest that malignant growth is a result of a series of genetic changes in cells, which cause the following six essential modifications in cell physiology: self-sufficiency in growth signals, inaccuracy in growth-inhibitory (antigrowth) signals, evasion of programmed cell death (apoptosis), limitless replicative potential, sustained angiogenesis, and tissue invasion and metastasis.2

Cancers are most commonly classified by the primary site of occurrence, but they are also secondarily grouped by the type of cell that the cancer is formed from. In this classification, a carcinoma is a cancer that begins in the epithelial cells that line the inside or outside of an organ. The two most common forms of carcinomas are squamous cell carcinomas and adenocarcinomas. Squamous cell cancers are formed by flat cells that resemble cells normally found on the surface of the skin or the linings of the throat, esophagus, lungs, anus, cervix, vagina, etc.; adenocarcinomas are cancers that develop from gland cells. Most cancers in the stomach and intestines are adenocarcinomas. The four most commonly occurring cancers in the United States—prostate cancer in men, breast cancer in women, lung cancer, and colorectal cancer—are all carcinomas. Cancer that develops from cells of the immune system found in the lymph nodes and other organs are called lymphomas; melanomas develop from cells that produce the skin’s tan; sarcomas develop from connective tissue cells that are usually present in tendons, ligaments, muscle, fat, bones, cartilage, and related tissue; and germ cell tumors develop in the testes for men or ovaries for women or in the parts of the body where these organs developed in the fetus.

In most cases, cancer cells form solid tumors. The diagnostic work-up in a patient newly diagnosed with cancer usually includes an assessment of the stage of the cancer. Cancer staging is a way to describe the severity of the disease. It also determines the treatment modality. Most tumors can be classified as Stage 0, Stage I, Stage II, Stage III, or Stage IV. Increasing stage denotes increasing severity, with Stage IV indicating that the cancer has spread to distant organs or metastasized.

The choice of a treatment for cancer varies with both the site of primary origin and the type of cancer. Most common cancer treatments consist of combinations of three components: (1) surgery to remove as much of the cancerous tissue as possible, (2) radiation to kill or slow the growth of cancerous tissue that cannot be accessed safely through surgery, and (3) tissue-specific chemotherapy to kill cancer tissue through a system-wide administration of “anticancer” drugs. Chemotherapy is always a part of the regimen when a patient has metastatic cancer (i.e., their disease has spread from the primary organ to a distant organ). Patients who are diagnosed as having Stage III or Stage IV cancer usually have metastatic cancer. There are curative treatments for some metastatic cancers; if a curative treatment is not available, it is still possible to treat the metastatic cancer and slow the progression of the cancer to increase survival or relieve symptoms and improve quality of life.

As the understanding of the molecular functioning of cancer cells increases, targeted therapies designed to attack specific characteristics of a cancer cell are being added to treatment regimens. Drugs used in these regimens are targeted to attack specific functions of cancer cells and leave healthy cells alone. Cancer cell type and primary site both affect the efficacy of targeted therapies. In order to design the most effective treatment regimen for a patient with metastatic cancer, it is therefore important to know the site of the primary tumor or at least the cancer cell type.

### Cancer of Unknown Primary Site

A metastasized tumor shares some molecular characteristics, such as chromosomal rearrangements and expressed proteins, with the primary tumor. Thus, a metastatic breast cancer in the lung will have characteristics of breast cancer, not lung cancer. It is still considered and treated as breast cancer. The most likely sites of metastasis of various primary tumors are well known (Table 1).3 Some cancer patients present in clinic with metastatic tumors in one or more sites without a primary tumor. These cancers are called cancers of unknown primary (CUP) site.

Table 1 Common sites of metastasis for different primary sites

Primary Cancer | Main Sites of Metastasis
Breast | Lung, liver, bones
Colon | Liver, peritoneum, lung
Kidney | Lung, liver, bones
Lung | Adrenal gland, liver, lung
Melanoma | Skin, muscle, liver
Ovary | Liver, peritoneum, lung
Pancreas | Liver, lung, peritoneum
Prostrate | Lung, liver, bones
Rectum | Liver, peritoneum, adrenal gland
Stomach | Liver, peritoneum, lung
Thyroid | Lung, liver, bones
Uterus | Liver, peritoneum, lung

Source: National Cancer Institute.

Naresh4 hypothesized that in CUP the primary tumor is not able to develop a good supply of blood and nutrients for itself (angiogenic incompetence), leading to marked cell death and cell turnover. The primary tumor remains microscopic or disappears after seeding the metastasis. Naresh4 suggests that the metastatic potential of the cells is not activated until the cells evolve and develop into angiogenic-competent cells. This results in a biologically advanced tumor that acquires a metastatic phenotype. Once this type of cell has developed, there is a rapid growth of the metastatic tumor. Emerging data suggest that the propensity to metastasize might be hardwired early in the disease process,5 which suggests that in CUP the primary tumor has a “poor prognosis” signature and is unable to establish itself but can metastasize to various organs.

The American Cancer Society estimated that more than 30,000 cases of CUP were diagnosed in 2011.^1^ Tong et al.6 concluded that the number may actually be as much as 53,000 new cases of CUP among Medicare patients a year. Some CUP patients may be treated as “known primaries” for pragmatic reasons, even though the primary site is not conclusively identified. If these patients are included in the count, Greco7 suggests that there may be as many as 100,000 cases of CUP per year in the United States. Prognosis for CUP patients is generally poor; the median survival for all types of CUP is about 9 to 12 months.

### Diagnosis and Treatment of CUP

A patient should be diagnosed as having CUP only after a thorough examination and history have ruled out a primary site. NCI guidelines call for the initial evaluation of a CUP to include a tumor biopsy; a thorough history; a complete physical examination that includes head and neck, rectal, pelvic, and breast examinations; chest x-rays; a complete blood cell count; urinalysis; and examination of the stool for occult blood.8

Chemotherapy is the most common option used to treat CUP. As more targeted and effective therapy for specific cancer types becomes available (renal, lung, breast, colorectal, stomach, and others), identification of the primary site of a CUP could improve staging and prognosis for many patients.7 It can identify clinical trials for which the patient is eligible. A more accurate test for CUP would also decrease the need for further diagnostic procedures and reduce the time between excision of the cancer and initiation of the treatment. Traditional methods of identifying the tissue of origin (TOO) for CUP have had limited success,9 and considerable research has been done to improve available techniques and develop new techniques.

### Tests to Identify Primary Site

The most commonly used techniques to identify TOO include light microscopy, immunohistochemistry (IHC) staining, and computed tomography (CT) or positron emission tomography (PET) imaging.

#### Light Microscopy

CUP cancer tissue specimens from a fine needle aspiration or core needle biopsy are subjected to light microscopic examination after they are stained with hematoxylin and eosin or other histologic or cytologic stains. After light microscopy examination, approximately 60 percent of CUP cases are reported as adenocarcinomas and 5 percent as squamous cell carcinomas. In the remaining 35 percent, light microscopy allows less definitive conclusions—poorly differentiated adenocarcinoma, poorly differentiated carcinoma, or poorly differentiated neoplasm.9

#### IHC Tests

IHC stains are an important complement to light microscopy in the evaluation of CUP. IHC staining methods include use of fluorophore-labeled (immunofluorescence) and enzyme-labeled (immunoperoxidase) antibodies to identify proteins and other molecules in cells. IHC is used in surgical pathology to determine cancer cell types, cancer subtype classifications, and possible cell of origin in metastatic cancer of unknown or undetermined primary site.9 IHC markers help define tumor lineage by identifying antigens expressed in the tumor that are specific to tumor type. Cytokeratin subtype is a commonly used IHC marker for identifying the primary site in CUP. The 20 subtypes of cytokeratins have different expression profiles in various cell types and tumors. Cytokeratins are typically expressed in carcinomas, whereas other immunohistochemical markers characterize sarcomas, melanomas, and hematologic malignancies. For example, cytokeratin 20 (CK20) is normally expressed in the gastrointestinal (GI) epithelium, urothelium, and Merkel cells, while cytokeratin 7 (CK7) is found in tumors of the lung, ovary, endometrium, and breast. Figure 1^9^ demonstrates the approach to IHC testing using CK7 and CK20 in CUP. This initial IHC test narrows the possible sites, then sequential testing with the additional markers listed in Table 2^9^ further narrow the probable site of the primary. A recent meta-analysis found that IHC staining correctly identified the site of origin of 82 percent of blended primary and metastatic tumors and 66 percent of metastatic cancers.10 Dennis et al.11 demonstrated that an IHC panel of 10 marker stains correctly classified the site of origin in 88 percent of adenocarcinomas.

Figure 1 Using presence and absence of CK7 and CK20 to narrow the field of possible primary sites in CUP patients

Figure 1 shows how the immunohistochemical stains cytokeratin 7 and cytokeratin 20 are used to narrow the field of possible primary sites in cancers of unknown primary site.

Table 2 Markers used to narrow possible primary sites after tissue is tested for CK7 and CK20

Site | IHC Marker
Urothelial tumors | UROIII, THR, HMWCK
Breast carcinoma | GCDFP-15, ER, PR
Lung(mainly adenocarcinoma) | TTF-1, surfactant A and B
Medullary thyroid carcinoma | TTF-1, calcitonin
Merkel cell carcinoma | CD117
Hepatocellular carcinoma | Hep par-1
Prostate carcinoma | PSA, PAP
Cholangiocarcinoma | CK19
Mesothelioma | Calcetrin

Abbreviations: ER = estrogen receptor; GCDFP-15 = gross cystic disease fluid protein-15; HMWCK = high molecular weight cytokeratin; PAP = prostate acid phosphatase; PR = progesterone receptor; PSA = prostate specific antigen; THR = thrombomodulin; TTF-1 = thyroid transcription factor-1; UROIII = uroplakin III.

#### CT Scans

CT scans combine X-rays taken from various angles into three-dimensional images, providing better views of organ structure, and can therefore detect much smaller tumors than a chest x-ray. The vast majority of CUPs that are identified are lung or pancreatic carcinomas, so chest and abdomen CT scans are routinely done to detect occult primary tumors. For women, the routine workup for a CUP also includes mammograms and pelvic CT scans. Physical exam, a thorough medical history, and knowledge of common primary-metastasis relationships can suggest areas for additional CT scans.

#### PET Scan

A PET scan uses radioactive materials to measure body functions, such as blood flow, oxygen use, and sugar (glucose) metabolism. The most common radiotracer in use today is 18F-fluorodeoxyglucose (18F-FDG), which is a radio-labeled sugar (glucose) molecule. Imaging with 18F-FDG PET is used to determine sites of abnormal glucose metabolism and can be used to characterize and localize many types of tumors.12 PET imaging alone can detect 8 percent to 53 percent of CUP primary sites; it has been most effective in detecting occult primaries in the head and neck.12 Trials that have used PET for patients with suspected occult primaries in the head and neck detected a primary tumor in 20 percent to 31 percent of the cases with a false positive rate of about 20 percent.12 A few centers have used whole body PET/CT scans to detect the primary site in patients with CUP, with a success rate of 21 percent to 35 percent.12, 13

#### Molecular and Genetic Tests

A clinically detectable cancerous lesion is the result of a succession of genetic changes that disrupts the normal process of cell decay and death. Cytogenetic analysis is the traditional method of identifying these changes and associating them with specific cancer types.14 Ramaswamy et al.15 found that a gene expression signature distinguished primary from metastatic adenocarcinomas. Similar studies by other groups suggested that gene expression profiles in metastatic tissue could identify the site of the primary tumor by comparing the known profile of different primary cancers to the one expressed by the CUP tissue and identifying the primary with the closest match.16

New molecular genetic TOO tests use molecular marker panels that measure patterns of gene expression and regulation. Test analytes, methodology, and panel composition (i.e., the specific markers included) and size (i.e., number of markers) differ between tests. The measurement of interest for a specific marker may be qualitative (presence or absence of the marker) or quantitative (the total estimated number of copies of the marker or the number of copies relative to another marker). Statistical algorithms analyze the pattern of markers and estimate the likelihood the tumor is derived from a specific tissue and is of a specific type. Several issues are still to be determined with respect to the validity and the utility of these tests.

### Objectives of the Review

In this technology assessment we report the results of our review of the existing literature based on the key questions (KQs) identified in the protocol, assess the quality of evidence for each question, and synthesize the results across studies for the same test using a meta-analytic approach when there is sufficient information across the studies. The approach used for the meta-analysis of the results in the review is described below. No medical devices are included in this review.

#### Meta-Analysis

Synthesis of medical test data typically focuses on measurements of test performance, that is, its sensitivity (identifying true positives); specificity( identifying true negatives); positive predictive value (probability that an individual actually has the disease if the test is positive); negative predictive value (probability that an individual does not have the disease if the test is negative); positive likelihood ratio (ratio of people with disease who have a positive test to those without disease who have a positive test), and negative likelihood ratio (ratio of people without disease who have a negative test to those with disease who have a negative test). The Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Medical Test Reviews (MGMTR)17 recommends summarizing sensitivity and specificity across studies and then calculating the other test performance measures using the summary sensitivity and specificity.

Sensitivity and specificity can be summarized as a summary point when the estimates across do not differ widely. In cases where the estimates vary widely or when the test threshold varies by study, the summary may be most usefully represented by a line that describes how the average sensitivity varies with average specificity. In both cases, the MGMTR recommends using a multivariate meta-analytic approach to obtain summary estimates of sensitivity and specificity. This is because although sensitivity and specificity of a test are independent within a study, they are not independent quantities across studies; they are usually negatively correlated especially when different thresholds for positivity are used in different studies. This suggests that aggregating these values across studies without allowing for correlation across studies is likely to produce biased summary estimates.

The MGMTR recommends two families of hierarchical models: the bivariate model and the “hierarchical summary receiver operating characteristic” (HSROC) model. In the absence of covariates, these families are mathematically equivalent. The covariates in these models would represent variables that contribute to the heterogeneity of the estimates (e.g., differences in patient selection, methods of verification and interpretation of results, clinical setting and disease severity).

The traditional definitions of sensitivity and specificity used in the context of diagnostic medical tests do not quite fit the use of the genetic tests used to detect the TOO in CUP cases. The test is designed to include or exclude a tissue as the TOO. The test result is the probability that the origin of a tumor is from a particular site, so the call either includes or excludes a site of origin. The sum total of probability calls from this test adds up to 1. In a typical study, sensitivity and specificity are independent, because sensitivity is measured in cases and specificity is measured in controls. In TOO tests, sensitivity and specificity are not independent, because the probability of identifying the TOO is not independent of excluding another tissue on the test’s panel of tissues. The most appropriate test performance measure in this case is the proportion of tissue identified accurately with confidence bands around this measure of accuracy. The studies in the review used the terms sensitivity and accuracy interchangeably. Although a few studies report specificity, it is used as a measure of the accuracy of exclusion of a tissue and is correlated to the accuracy of inclusion. The issue of different thresholds across various studies is not applicable in this case. A tissue is included, excluded, or indeterminate.

In the meta-analysis presented here, we therefore chose to represent a single summary accuracy measure and its 95% CI across the various studies. We have done this only for clinical accuracy. Nine studies are summarized to obtain a summary measure of test accuracy in classifying tumors of known tissue for PathworkDx; the corresponding numbers for miRview mets and CancerTypeID are four and six, respectively. PathworkDx TOO and CancerTypeID had multiple studies from which the data might have been summarized with a meta-analysis with respect to the accuracy of diagnosis in CUP cases. However, the diagnosis used as a gold standard was inconsistent and incomparable among the studies. We therefore decided against creating a summary estimate.

## Key Questions and Population, Intervention, Comparator, Outcome, Timing, and Setting (PICOTS)

The KQs were revised during protocol development from those included in our original scope of work. The revisions aimed to (1) rephrase questions such that they can be answered by an evidence review, (2) incorporate assessment of the statistical algorithms described above, and (3) revise or remove questions not relevant in the context of genetic TOO tests. In conducting our review, we also identified some literature on genetic testing to diagnosis small round cell tumors. This literature and our findings are discussed in the brief report titled Genetic Testing in the Diagnosis of Ewing Sarcoma (Appendix G).

### KQ 1 What genetic or molecular TOO tests are available for clinical use in the United States and what are their characteristics?

We searched the Internet and the peer-reviewed literature to identify genetic or molecular TOO tests. For each test, we reported the marketer of the test, whether it is marketed as a laboratory service (test performed only at the developing laboratory) or as a testing kit (test can be performed by hospital or other labs), and its FDA status and availability in the United States. We summarized its sample requirements, number and type of analytes, the types of tumors that can be identified by the test, and how many tumors of each type are included in the reference database for the test. Finally, we described how the results are reported and how the laboratory results are translated into reported results.

### KQ 2 What is the evidence on the analytic validity of the TOO tests?

To answer this question, we considered the tissue sample acceptance/rejection criteria, the measurement accuracy for individual markers (mRNAs or microRNAs) used in the test, the accuracy and specificity for each marker at the assay conditions, the degree of interlaboratory agreement, the uniqueness of the panel markers used in the panel and their robustness to contamination, and whether any antibodies used are monoclonal and their robustness. We also considered the quality control steps used for the individual markers and for the overall assay; quality control measures included the proportion of the probes or antibodies that must return a valid result for the assay to be considered valid and the stability of the multimarker panels’ precision and accuracy across time.

### KQ 3 What is the evidence regarding the accuracy of genetic TOO tests in classifying the origin and type of CUP?

a. Does it differ by tumor origin?
b. Does it differ by patient age, sex, race, or ethnicity?

We based our answer to this question on how closely the experimental process used to develop the statistical classification models adhered to the guidelines published by Simon et al.18 and on the accuracy and specificity of the genetic TOO test when compared with a gold standard of cancers of known primary sites, such as IHC staining, imaging studies, or other methods in current clinical use.

### KQ 4 What is the evidence that genetic TOO tests change treatment decisions and improve clinical outcomes?

We considered clinical trials and epidemiology studies that compare treatment decisions and health outcomes when genetic TOO tests are used instead of or in addition to other methods of identifying the primary site of the tumor.

### KQ 5 Is the evidence regarding genetic TOO tests relevant to the Medicare population?

We compared the characteristics of participants in the studies of genetic TOO tests to the core Medicare population (i.e., individuals 65 years and older) in terms of patient age, race, and primary diagnosis. We also considered whether studies of TOO tests include cancers that occur in the core Medicare population.

## PICOTS

### Population for Key Question 1 through Key Question 4

Patients of any age whose cancer is first diagnosed from a metastatic tumor for which the primary site cannot be found and the TOO is unknown.

### Population for Key Question 5

Patients 65 and older whose cancer is first diagnosed from a metastatic tumor for which the primary site cannot be found and the TOO is unknown.

### Interventions

The use of genetic or molecular tests for identifying the tumor’s TOO in addition to or instead of other methods such as IHC staining or PET imaging.

### Comparators for Key Question 3

The comparison standard used in the included studies, such as the ability of tests to correctly classify cancers of known origin or the determination of TOO by IHC staining, PET imaging, or other methods.

### Comparators for Key Question 5

Treatment or health outcome for patients that did not have genetic or molecular TOO testing or that had a different test.

### Outcomes, Intermediate

- Treatment or management decisions

### Outcomes, Health

- Response to treatment (remission or tumor shrinkage)
- Recurrence
- Length of survival
- Mortality
- Quality of life

### Timing

- Followup of any length after test results received

### Setting

- Includes studies conducted in the United States or internationally
- Includes testing on patients admitted to the hospital or treated as outpatients