# Discussion

## Summary of Evidence

Table 16 summarizes our findings, which are discussed below.

Table 16 Overview of study outcomes

Key Question | Number of Studies | Conclusion | Strength of Evidence
KQ 2. Analytic validity: CancerTypeID | 1 | Only one study that was conducted by manufacturer of test. Limited measures of analytic validity reported and impossible to assess consistency of those measures across studies. | Insufficient
KQ 2. Analytic validity: miRview mets | 4 | Four studies each reported different measures of analytic validity. Impossible to evaluate consistency of reported measures of analytical validity across studies. | Insufficient
KQ 2. Analytic validity: PathworkDx | 3 | Three papers reported measures of analytic validity. There is moderate consistency between studies of interlaboratory reproducability. The reported precision in these three papers is high. | High
KQ 2. Analytic validity PathworkDx Endometrial | 1 | One study reported on the analytic validity of a PathworkDx Endometrial test. The reported precision of the test is high, but there is insufficient evidence to assess analytic validity. | Insufficient
KQ 3a. Adherence to Simon guidelines: CancerTypeID | 2 | Report on the development of the algorithm has sufficient detail on development and validation to assess the validity of the process. Development met the Simon3 criteria. | High
KQ 3a. Adherence to Simon guidelines: miRview mets | 2 | Report on development of algorithm has sufficient detail on development and validation to assess the validity of the process. Development met the Simon3 criteria. | High
KQ 3a. Adherence to Simon guidelines: PathworkDx | 2 | Report on development of algorithm does not have sufficient detail on development and validation to assess the validity of the process. | Low
KQ 3a. Adherence to Simon guidelines: PathworkDX Endometrial | 1 | Report on development of algorithm does not have sufficient detail on development and validation to assess the validity of the process. | Low
KQ 3b. Accuracy of the TOO test in classifying the origin and type of tumors of known primary site: CancerTypeID | 7 | Seven studies representing 1,476 tissue samples compared the ability of tests to identify origin of tumor in tissues of known origin. All report accuracy of inclusion. Accuracy of exclusion reported in two studies. | High
KQ 3b. Accuracy of the TOO test in classifying the origin and type of tumors of known primary site: miRview mets | 4 | Two independent studies representing 898 tissue samples tested the ability of the miRview to identify site of origin in tissues of known origin. Accuracies of inclusion and exclusion are reported for both. | High
KQ 3b. Accuracy of the TOO test in classifying the origin and type of tumors of known primary site: PathworkDx | 9 | Nine studies representing 1,247 tissue samples report on the ability of the test to identify the origin of tumor in tissues of known origin. Accuracy of included tissue is reported in all studies. Accuracy of excluded tissues reported in two studies. | High
KQ 4. Percentage of cases for which a TOO test identified a TOO | 17 | Fifteen studies rated fair provided evidence on this question. The ability of the test to identify a TOO was judged using different criteria in different studies. | Moderate
KQ 4. Percentage of CUP cases for which the TOO identified by the test was independently confirmed | 6 | Five studies all rated fair provided evidence for this question. Gold standard varied across studies and precision across studies was moderate. Accuracy ranged from 57% to 100%. | Low
KQ 4: Percentage of CUP cases where TOO modified diagnosis | 6 | Four studies rated fair and one poster rated good provided evidence for this question. Some explored potential changes; others actual changes. The reported percentage of changes ranged from 65% to 81%. Response rates in the survey were fairly low. | Low
KQ 4: Percentage of CUP cases where test was considered clinically useful by physician or researcher | 6 | All studies found test clinically useful in a proportion of cases. Clinical usefulness was measured differently in each study. Wide estimate in the proportion of cases where test was useful. | Low
KQ 4: Change in treatment decisions | 5 | Studies have small samples, varied study designs and measures of effect on treatment decisions, making it difficult to draw conclusions on any of the tests. | Insufficient
KQ 4: Treatment response: Tissue-specific treatment based on TOO test compared with usual treatment for CUP cases | 4 | Small samples, insufficient studies to draw conclusions on any of the tests. Only one study has a control; all others use historical controls. | Insufficient
KQ 4: Change in survival | 5 | Small samples, insufficient studies to draw conclusions on any of the tests. Most use historical controls. | Low
KQ 4: Change in disease progression | 1 | Small samples, insufficient studies to draw conclusions on any of the tests. | Insufficient
KQ 5: Applicability | 22 | Almost all studies included patients age 65 and older and both male and female patients. The studies that reported race included mostly Caucasian patients. | High

## Key Question 1 TOO Tests

Three broadly applicable tissue of origin (TOO) tests are currently available for clinical use in the United States. These tests identify from 15 (PathworkDx) to 27 (CancerTypeID) primary tumor sites. All three tests identify bladder, breast, kidney, melanoma, lung, ovary, pancreas, prostate, sarcoma, testis, or thyroid primary sites. Between 1980 and 2000, eight primary sites (lung, pancreas, kidney/adrenal, stomach, bowel, liver or bile duct, ovary or uterus, and prostate) accounted for 79 percent of primary sites identified by autopsy.25 These sites are at least partially identified by all three tests. PathworkDx TOO does not list adrenal tumors as an identified site, and miRview mets^2^ does not list endometrial tumors.

Chromosome analysis by G-banding, fluorescent in situ hybridization (FISH), or comparative genomic hybridization can be used to identify tumor types associated with specific chromosomal rearrangements. In cases of cancer of unknown primary (CUP) sites, these tests are much less likely to predict a tumor identification than any of the genomic tests (25% versus > 80%). Chromosomal analysis can be very useful when differential diagnosis includes a tumor type associated with a specific genomic rearrangement, such as in Ewing sarcoma (see Appendix G).

## Key Question 2 Analytic Validity

Ten articles24, 28–36 reported data on the analytic validity of the genomic TOO tests. The information presented in the articles suggests the tests are analytically valid and the described quality control measures for the tests are appropriate. The evidence for each test is limited to one or two studies, however. We were only able to assess the consistency of measures of analytic validity across studies for the PathworkDx TOO test. We considered the evidence of analytic validity for the PathworkDx TOO test as high, but we felt evidence was insufficient to determine the analytic validity of the CancerTypeID and miRview mets or mets^2^ tests (Appendix F). Only one article24 reported on the analytic validity of the CancerTypeID TOO test. Three studies reported on the analytic validity of the miRview mets and one on the second-generation mets^2^ test, but the different studies of the mets test did not report the same measures of analytic validity. One study34 reports on analytic reproducibility between testing platforms and sample times. A second reports on interlaboratory reproducibility,35 and a third36 reports the quality control measures for the assay. Three studies29, 30, 33 reported on the analytic validity of the PathworkDx TOO test. Two studies30, 33 reported on interlaboratory and interassay reproducibility and quality control measures. Interlaboratory correlation between the similarity scores is high, consistent in direction, and of moderate precision.

## Key Question 3a Statistical Validity

One good study,37 described the development of the algorithm used in CancerTypeID. The normalization uses five housekeeping genes, and although it is stated that these were found to be stable in multiple tissues, it is not clear if a formal experiment was done to test the stability of the housekeeping genes under multiple conditions. A modification of the algorithm is described in Erlander et al.24 The methods of dimension reduction, classification, and validation are clearly stated, and overall the published evidence on the quality of the algorithm is high.

Rosenfeld et al.,34 graded good, describe the development of the algorithm for miRview mets. All aspects of the development of the algorithm are well described, and the published evidence on the quality of the algorithm used in miRview is high.

Dumur et al.67 and Pillai et al.,33 graded good, both describe the normalization process used in the PathworkDx TOO. The dimension reduction algorithm and the classification are considered proprietary and not described in enough detail to determine the appropriateness of the algorithm. The published evidence on the statistical validity of the algorithm is insufficient.

Lal et al.31 describe a modification of the PathworkDx TOO aimed at distinguishing ovarian cancers from endometrial cancers. As above, the dimension reduction algorithm and the classification are considered proprietary and not described in enough detail to determine the appropriateness of the algorithm. The published evidence on the statistical validity of the algorithm is insufficient.

## Key Question 3b Accuracy of the TOO Test in Classifying the Origin and Tissue of the Tumor

Six studies,24, 37, 41, 42, 47, 49 representing a sample size of 1,478 tissue samples, reported on the ability of the CancerTypeID test to identify the origin of the tumor in tumors of known origin. Based on these studies, with similar estimates of accuracy and the meta-analytic summary estimate 85 percent (83%, 86%), the evidence is high that CancerTypeID correctly identifies tumor type in known tissue nearly 80 percent of the time.

Four studies,32, 34, 35, 45 representing a total of 1,198 samples, reported on the ability of the miRview mets to identify the tissue of origin in tumors of known origin. Based on the similarity of the estimates of accuracy across studies rated both good and fair and the meta-analytic estimate of 85 percent 95% CI (83%, 87%), the evidence is high that miRview mets accurately identifies the tumor type in known tissue 85 percent of the time.

Nine studies,29, 33, 39, 40, 43, 44, 46, 48, 67 representing a total of 1,243 tissue samples, reported on the ability of the test to identify the origin of the tumor in tumors of known origin. Based on the similarity of estimates of accuracy across studies rated good and fair and the meta-analytic summary estimate of 88 percent, 95% CI (86% to 89%) the evidence is high that the PathworkDx test correctly identifies the tumor source 88 percent of the time, 95% CI (86% to 89%).

## Key Question 4 Diagnosis

Moderate evidence supports the ability of TOO tests to predict the TOO and to affect the diagnosis of CUP cases. As noted in the introduction, CUP cases by definition have not been diagnosed even after extensive clinical and pathological evaluation. The TOO of many cases of CUP are not diagnosed even at autopsy.25 Therefore, a test may be useful in evaluating CUP cases even if it provides a diagnosis in a minority of cases. The genomic tests predicted a TOO in 57 percent39 to 100 percent52 of cases. G-banded chromosomes predicted a TOO in 25 percent14 of CUP cases. The TOO test provided a diagnosis in 29 percent to 94 percent of cases without a pretest diagnosis24, 39, 53, 55, 57 and confirmed one of multiple differential diagnoses in 44 percent to 74 percent of cases.24, 57, 58 It changed the diagnosis in 17 percent to 55 percent of cases with a specific diagnosis prior to testing.29, 53, 55–57 In 26 percent to 79 percent of cases, the test did not change the pretest diagnosis.24, 29, 36, 53, 55–57

Low evidence supports the accuracy of the TOO prediction in CUP cases and the overall clinical utility of the tests. A confirmatory diagnosis was available in 10 studies,24, 29, 36, 39, 45, 50, 51, 53, 54, 58 and the predicted diagnosis was confirmed in 48 percent24 to 96 percent29 of cases. One study55 surveyed physicians and found that two-thirds of physicians reported the test was useful clinically. In two studies, the study authors assessed the utility of the case results and reported the case would have been clinically useful in 2 of 7 (29%)39 and 16 of 21 (76%)54 cases.

## Key Question 4a Treatment

Low evidence supports the premise that TOO results affect treatment decisions. Laouri59 reported that TOO test results changed the treatment recommendations (based on National Comprehensive Cancer Network guidelines) in 81 percent of cases. Nystrom et al.55 surveyed physicians who had ordered a TOO test result and found that the test results had changed management decisions in 65 percent of cases. Only 21 percent of surveyed physicians responded to the survey, however.

In a preliminary report of treatment response among patients who received assay-directed treatment, 41 percent responded to therapy; no comparison group was available. Three studies58, 62, 63 examined treatment decisions and response among cases with a colorectal cancer gene expression profile. Only one study63 included a comparison group; they found much higher response to treatment among patients who received colorectal-specific treatment compared with patients who received empiric therapy. The other two studies found response to colorectal-specific therapy was around 70 percent, but these studies had no control group.58, 62

## Key Question 4b Outcomes

The evidence for this question was limited. Seven studies,14, 26, 55, 58, 62, 63, 65 one14 rated as good and six26, 55, 58, 62, 63, 65 rated fair, provided evidence on this question. There is low evidence that changing from empiric CUP therapy to site-specific therapy post TOO increases survival by between 2 to 3 months. Most of the evidence is based on surveys of doctors or retrospective analysis. As discussed by Hainsworth et al.,65 in many cancers, empiric CUP therapy and site-specific CUP therapy is identical and the subpopulation of patients with CUP who would benefit from site-specific therapy is very small. Therefore, it is unlikely that there will be a prospective study that will be large enough to assess the effect of the TOO test and subsequent management on patient outcomes.

## Key Question 5 Applicability

Twenty-two studies14, 24, 29, 31, 33, 36, 40, 42, 44, 47–49, 51–55, 57, 62, 63, 65, 66 provided information on the age of the cases in their study (Table 15). All but one48 included patients age 65 years or older, the Medicare core population. All of the studies of tests applicable to both cancers that provided information on the sex of the cases included both male and female cases. The studies and the TOO test panels include cancers specific to women (breast, ovarian) and to men (prostate, testicular). Only two studies33, 49, 55 provided information on ethnicity. In both of these studies, the majority of the patients were Caucasian. Pillai et al. included 68 (15%) patients of Asian-American or Pacific Islander ancestry. One study49 was conducted in China, so the patient population would be expected to be predominantly Chinese.

### Summary of Accuracy

A majority of the studies that contributed to the assessment of accuracy of the tests in identifying the origin of the tumor when the tissues were of known origin were rated good. Twenty studies were graded good and one was graded fair. The estimates of accuracy were consistent across all the studies, and the method used to determine accuracy was valid. The summary estimates of accuracy in known tissue for all the tests were 84 percent for CancerTypeID, 87 percent for miRview mets, and 87 percent for PathworkDx.

The accuracy of the TOO call by the tests in CUP cases is not as easily determined. The studies that examined the accuracy of the TOO call variously used the following gold standards: (a) the discovery of a latent tumor post TOO test that confirmed the TOO result,51, 58 (b) improved response to tissue-specific treatment regimens,63, 64 or (c) consistency between the clinicopathological presentation and evidence of accuracy of the test.24, 29, 36, 50, 54, 57 The first of these is clearly a legitimate way to assess accuracy but will only rarely be available. Response to a specific treatment regimen is often used by clinicians to indicate differential diagnosis, particularly when a diagnosis is difficult to make. Response to treatment is not a valid gold standard for a diagnostic test, however. Similarly, consistency with clinicopathological features is of questionable validity, because the TOO test would not have been ordered if the clinicopathological features definitely identified the TOO. Given the rarity of cases for which a true gold standard is available, the accuracy of the TOO call by these tests will always be difficult to assess directly. The greater need is to determine if the tests are providing added benefit in diagnosing true CUP cases.

#### Gaps and Issues in the Literature on TOO Tests

Overall, the studies of the TOO tests were well designed and of fair to good quality. The primary concern with this body of literature is that all but one39 of the published studies either included authors employed by the test manufacturers or were funded by the manufacturers. Studies with findings that questioned the value of these tests may not have been published. It is notable that the study by Beck et al.,39 which received only equipment and assay materials from the test manufacturer, presented the most negative view of the utility of the test. We included abstracts and poster presentations in our review to increase the likelihood of identifying studies with negative results, but we cannot rule out the possibility of bias toward publication of positive studies.

The dominence of studies funded or conducted by the test manufacturers is due in part to the relative immaturity of the literature on these tests. Most published studies examined analytic validity or clinical validity; such studies can be expensive to conduct and are unlikely to be independently funded. Studies of clinical utility need to be free of potential conflicts of interest, it may also be easier to obtain independent funding for studies of clinical utility than studies of test validity. If funding by the test manufacturers is necessary, the credability of the studies would be increased if the funding mechanism and requirements were as transparent as possible.

The evidence for the analytic validity for each test is limited to one or two studies. The information presented in the articles suggests the tests are analytically valid and the described quality control measures for the tests are appropriate. We were only able to assess the consistency of measures of analytic validity across studies for the PathworkDx TOO test. We considered the evidence of analytic validity for the PathworkDx TOO test as high, but we felt evidence was insufficient to determine the analytic validity of the CancerTypeID and miRview mets or mets^2^ tests (Appendix F). Only one article24 reported on the analytic validity of the CancerTypeID TOO test. In addition, the published information30, 33 on the development of the statistical algorithm used in the PathworkDx text was too limited to assess whether the development process met the Simon18 criteria.

The greater gap was in the data on clinical utility. Low evidence supports the premise that TOO results affect treatment decisions, response to therapy, or survival outcomes. All but one63 of these studies either do not have control groups or use historical controls. As discussed above, it is also acknowledged65 that the CUP test would affect treatment in a relatively small number of cases; therefore, a large-scale clinical trial, if ethical, is likely to be impractical. Nonrandomized prospective studies similar to the study by Hainsworth et al.65 that compare patients in empiric therapy to patients who opt for tissue-specific therapy as a result of a TOO test would be useful in improving evidence on utility. The clinical utility of these tests is still uncertain.

#### Summary of Findings

We assessed four tests in this review: cytogenetic analysis, CancerTypeID, miRview mets, and PathworkDx TOO. Of the three tests, CancerTypeID has the broadest panel with the ability to detect 29 different tumor sites. miRview mets has 25 tumor sites on its panel and PathworkDx has 15 tumor sites in its panel.

The literature on genetic tests for CUP is in its infancy. In studies comparing TOO test results to known tumor site or a well-defined, valid measure of accuracy, the tests demonstrated a high degree of accuracy. The available literature on the application of these tests to actual CUP cases is very limited, and some studies are difficult to interpret because they lack a gold standard for accuracy of the test’s call. Given the nature of the CUP, a diagnostic gold standard may not always be available.

In the absence of a good measure of the diagnostic accuracy of the test, a proxy measure of the utility of the test is its effect on treatment decisions and patient outcomes. The literature on the effect of the test on treatment decisions is very limited. There is some evidence that the test alters the treatment course from empiric therapy usually used in CUP to tissue-specific therapy.

Site-specific therapy and targeted therapy are not different for all cancers. This is true in the case of cancers such as breast, nonsmall cell lung cancer, ovarian, and bladder where the first-line empiric therapy for CUP and the target specific therapy are the same. As a result, the subset of CUP patients expected to benefit from target-specific therapy is expected to be very small.65

The effect of this change in therapy on outcomes is limited to five papers. There is low evidence that the site-specific therapies change outcomes. Although some research suggests there is a modest increase in survival (approximately 3 months), only one study with a control group compares outcomes between patients who received tissue-specific therapy and those who did not. This one focuses on colorectal cancer and does not have a large enough sample size.

As mentioned, one of the concerns is that all but one of the manuscripts reviewed had a possibility of publication bias in the available literature.

### Future Research

Most studies included in the current review were funded wholly or partly by the manufacturers of the tests. The most urgent need in the literature is to have research groups that have no evident conflict of interest evaluate the clinical utlity of the tests.

Because tissue-specific therapy would be the standard of care for a patient with a tissue-specific diagnosis, ethical considerations would probably rule out a controlled trial that randomized patients with tissue-specific diagnoses from a TOO test into empiric therapy or tissue-specific therapy. A prospective trial such as the one reported by Monzon et al.44 and Hainsworth et al.,65 but with an appropriate comparison group, may be the best design available.

Given the lack of a true gold standard to assess the clinical accuracy of a TOO, future research should focus on the benefits from the test to the patient in terms of effect on treatment decisions and resulting outcomes. These studies will help assess clinical value of the TOO tests.