# Genetic Testing in the Diagnosis of Ewing Sarcoma

## Genetic Testing in the Diagnosis of Ewing Sarcoma

### Introduction

Soft tissue small round cell tumors (SRCTs) are a heterogeneous group of neoplasms that predominate in childhood and adolescence and share similar morphological features, consisting of dense proliferation of small undifferentiated round cells. Rhabdomyosarcomas, peripheral neuroepitheliomas, Ewing sarcoma (ES) family, and non-Hodgkin’s lymphomas are the prototypic SRCTs.1, 2 The recently described desmoplastic SRCT and rhabdoid tumors are SRCTs. The tumors that make up this group are listed in Table G-1.^2, 3^

Table G-1 Small Round Cell Tumors

Ewing sarcoma
Peripheral neuroectodermal tumor
Rhabdomyosarcoma
Synovial sarcoma
Non-Hodgkin’s lymphoma
Retinoblastoma
Neuroblastoma
Hepatoblastoma
Nephroblastoma

The most common SRCTs are the ES family. ES is a highly malignant tumor that commonly occurs in bone and soft tissues of children and adolescents but is occasionally seen in adults.4 It is the second most common pediatric bone tumor, accounting for 30 percent of all primary bone tumors. The ES family of tumors shares common immunohistology and molecular genetics and is considered to be one single group.5 The pathognomonic genetic marker of the ES family of tumors is the presence of the balanced translocation t(11;22)(q24;q12) that creates the EWS/FLI1 fusion gene and results in the expression of an abnormal protein. Approximately 85 percent of patients have the translocation t(11;22)(q24;q12), and 10 percent of patients have the translocation t(22;21)(q22;q12).6, 7 Molecular identification of the specific type of translocation, as well as tumor type, has prognostic significance for SRCTs. Patients with localized ES disease and tumor expressing type 1 EWS-FLI1 fusion transcript have longer disease-free survival than those with other fusion transcript types.8

The annual incidence of ES for 1973 and 2004 in the United States was 2.93 cases/1,000,000.^9^ ES is much more common in white populations and has a slight male predominance. In 15 percent to 30 percent of patients, metastases are present at the time of diagnosis. The most common sites for metastases are lungs (50%), bone (25%), and bone marrow (20%).10 The presence of metastases significantly affects long-term survival of patients with ES. Although multidisciplinary care has improved the survival rate of patients with localized ES to nearly 70 percent, these advances have not significantly changed the long-term outcome for those with metastatic disease, where 5-year survival remains less than 25 percent.11

Other mesenchymal tumors with specific translocations that should be considered in the differential diagnosis of ES include alveolar rhabdomyosarcoma and synovial sarcoma. Rhabdomyosarcoma is predominantly a disease of children and adolescents accounting for 5 percent to 8 percent of cancers in the pediatric population. Alveolar rhabdomyosarcoma is the most aggressive type of rhabdomyosarcoma and can be distinguished from other tumors by the detection of a PAX-FKHR gene translocation.12 Alveolar rhabdomyosarcomas containing a PAX7-FKHR translocation are usually less invasive and have a better prognosis than those with the PAX3-FKHR gene translocation.13

Similarly, synovial sarcomas frequently present during the second decade of life and should be considered in differential diagnosis along with other mesenchymal tumors that occur during adolescence. In synovial sarcoma, the SYT gene on chromosome 18 is fused to a member of the SSX gene family (t(X;18)(p11;q11)).12 Ladanyi et al. have reported that cases involving the SYT-SSX1 gene fusion have a worse prognosis.14

The diagnostic distinctions among the SRCTs are becoming increasingly important as specific, successful treatments are developed for each tumor. However, differential diagnosis has been difficult because the histologic criteria for distinguishing the subtypes are relatively subtle, and there is no well-established immunohistological marker that is differentially expressed by these tumors. Therefore, the identification of consistent chromosomal translocations and fusion regions associated with a majority of the tumor types is an important advantage in the differentiation of the SRCTs and a base for molecular testing.15 Molecular diagnostics, using either fluorescent in situ hybridization (FISH) to detect the fusion gene or reverse transcriptase polymerase chain reaction (RT-PCR) to detect its transcript, is developed for clinical use and is now a routine part of pathological examination. In addition to aiding in diagnosis, RT-PCR enables the detection of circulating metastatic tumor cells in blood.10 The growing needs for efficient genetic identification have led to development and application of commercially available molecular assays for detecting the chromosomal translocations and fusions in clinical samples of the SRCTs. The commercially available assays are listed in Table G-2.

### Methods

As discussed in Chapter 2, we designed the literature searches to identify papers on tissue of origin (TOO) tests for cancers of unknown primary site, which is the primary purpose of this review. The literature searches identified nine articles on genetic testing for the diagnosis of ES and other SRCTs. During the abstraction process, we became aware that a substantial portion of the literature on genetic testing for the diagnosis of SRCTs had not been identified by the searches. Upon further investigation, it became clear that the issues involved in assessing genetic testing for diagnosing small round cell tumors differed from those for CUP TOO tests. A systematic review of genetic testing for diagnosing small round cell tumors would have somewhat different key questions and required different search strategies. After discussion with Agency for Healthcare Research and Quality (AHRQ), we decided to focus resources on the CUP TOO test.

We report here on the limited review we completed on genetic testing for diagnosis of SRCTs. Literature search strategies, study eligibility, data management, data abstraction, and quality assessment of the articles were conducted as reported in the Methods chapter of the TOO report. We did not grade the strength of the evidence because the review is not comprehensive.

Table G-2 ES commercially available assays

Name of test | Manufacturer | How Marketed? | FDA Approval | Sample Requirements | Laboratory Analysis Method | Type of Tumors Identified | Number of Tumors in Reference Database | Reported Results | Statistical Analysis Method
EWSR1 (22q12) Gene rearrangement by FISH: Vysis LSI EWSR1 Dual Color Break Apart Probe | Abbot Molecular http://www.abbottmolecular.com/products/oncology/fish/vysis-ewsr1-break-apart-fish-probe-kit.html# | Kit | Approved | Formalin-fixed paraffin-embedded tissue | Fluorescence in situ DNA hybridization | ES Primitive neurodectodermal tumor Clear cell sarcoma | NA | Signal pattern | NA
EWSR1 (22q12) gene rearrangement by FISH | Quest Diagnostics Nichols Institute http://www.questdiagnostics.com/hcp/testmenu/jsp/showTestMenu.jsp?fn=16112.html&labCode=SEA | Service | Not submitted | | Fluorescence in situ DNA hybridization | ES Primitive neurodectodermal tumor Clear cell sarcoma | NA | Signal pattern | NA
ES by RT-PCR | ARUP Laboratories http://www.aruplab.com/guides/ug/tests/0051220.jsp | | | Fresh frozen tumor tissue. formalin fixed paraffin-embedded tissue block, or unstained sections on charged slides. 100 mg or 0.5–2.0 cm^3^ | Reverse transcription polymerase chain reaction/fluorescence monitoring | ES | NA | Not found | NA

Abbreviations: FISH = fluorescent in situ hybridization; NA = not applicable; RT-PCR = reverse transcriptase polymerase chain reaction

Tumor-specific rearrangements were first identified and tested using G-banded karotypes.14 Over the last two decades, however, fluorescent in situ hybridization (FISH) or reverse transcriptase polymerase chain reaction (RT-PCR) has become the technique of choice for identifying such gene rearrangements. Both of these techniques rely on nucleic acid probes that bind to the sample DNA. Nucleic acid probes may differ in length and sequence, which affects the precise area of binding. Because there is variation in the splice points between the two chromosome segments, the rearrangement may have different characteristics. The probes used in the tests affect the performance of the test, so combining evidence across tests that use different probes must be done with caution.

### Results

A kit is commercially available for FISH testing—the Vysis LSI EWSR1 Dual Color Break Apart Probe kit, sold by Abbott Laboratories—but some laboratories, such as the Mayo Clinic Medical Laboratories, develop their own probes. Quest Diagnostics offers FISH testing for ES as a laboratory test rather than as a kit. ARUP Laboratories offers both a FISH and an RT-PCR test for ES diagnosis.

#### Analytic Validity

We identified nine studies4, 12, 15–21 that examined the analytic validity of genetic tests (RT_PCR, FISH, or karotype) for the diagnosis of ES (Table G-3). Five studies12, 15, 18–20 were rated good, and four4, 16, 17, 21 were rated fair. All studies that performed RT-PCR used noncommercial probes for the analysis. Three good studies17, 19, 20 and two fair studies16, 21 reported on experience using the commercially available FISH Dual Color Break Apart Probe produced by Vysis, Inc. Mhawech-Faucegalia et al.19 compared the Vysis FISH probe to immunohistochemistry (IHC) analysis. They found that FISH performed poorly when tissue preservation was poor. Five of 58 analyses failed entirely, and a translocation was detected in only 50 percent of cases. The specificity of FISH was 100 percent.

Three studies compared the ability of the Vysis, Inc. break apart EWS (22q12) FISH probe and RT-PCR to detect pathonomic translocations in ES and other SRCTs. Neither test was clearly better. Patel et al.20 found that RT-PCR analysis detected fusion transcripts in all eight of their samples, but the FISH probe detected translocations in only seven (88%) samples. Gamberi et al.17 reported on their clinical experience. RT-PCR was performed first; FISH, using the Vysis, Inc. probes, was performed if the sample was inadequate for RT-PCR or if RT-PCR was negative. RT-PCR or FISH produced interpretable results in 188 of 222 ES cases (85%). RT-PCR detected a transcript in 121 cases, and FISH identified a translocation in 23 more cases. Bridge et al.16 examined the sensitivity and specificity of the Vysis, Inc. FISH break apart probe, FISH fusion, and RT-PCR. The gold standard was the histopathologic diagnosis. They reported that 12 percent to 16 percent of cases were uninformative, depending on the technique, and that the concordance between FISH and RT-PCR was 67 percent, primarily due to the lower sensitivity of the RT-PCR assay.16 Sensitivity and specificity of the two FISH assays were equivalent. The way the number of cases is reported is very unclear, however, and the proportions could not be verified from the reported data. Yamaguchi et al.21 also compared RT-PCR with the Vysis Inc. FISH probe. FISH detected translocations in 14 of 16 ES/primitive neuroectodermal embriogenic tumor (PNET) cases. RT-PCR results were only available for seven cases; a transcript was detected for five. Each method detected one translocation that was not detected by the other method.

Table G-3 KQ 3. Evidence of analytic validity of TOO tests for ES

TOO Test, Author, Year Study Dates, Region | Sample Characteristics | Cancer/Tumor Types | Range of Sensitivity for Measuring the Markers | Range of Specificity for Measuring the Markers | QC Measures for Markers | Other
ES (RT-PCR) Barr, 1995^15^ 1988–1993 U.S. only Good | Age: NR Female: NR N: 79 | Alveolar rhabdomyosarcoma, embryonal rhabdomyosarcoma, ES, desmoplastic small round cell tumor, undifferentiated small round cell tumor, other | Translocations identified on karotype: 11/11 Fusions not identified by karotype: 4 Translocations identified by FISH: 11/12 | RT-PCR compared with FISH: 19/19 | Technical success RT-PCR: 79/80 FISH: 31/41 Karotyping: 29/74 | NR
ES (RT-PCR) Bridge, 2006^16^ 2004 U.S. only Fair | Age: NR Female: NR N: 66 | ES/primitive neuroectodermal tumors undifferentiated round cell sarcomas, small cell carcinomas, neuroblastomas, alveolar rhabdomyosarcomas, fibrosarcomas, malignant teratoma | ES/primitive neuroectodermal tumors: FISH break apart: 20/22 FISH fusion: 20/22 RT-PCR: 7/19 [recreated from article; does not match sensitivity in Table 1] | FISH break apart: 36/36 [recreated from article] FISH fusion: 34/34 [recreated from article] RT-PCR: 85% [stated in article; unable to determine actual numbers] | Technical success of FISH break: 59/67 Technical success of FISH fusion: 56/66 Technical success of RT-PCR: 36/43 | NR
ES (RT-PCR) Delattre, 1994^4^ 1993 NR Fair | Age: Range: 1 to 48 Median: 13 Female: NR N: 114 | Osseous ES, atypical ES, peripheral primitive neuroectodermal, not ES tumors, lacking hallmarks of specific disease | t(11:22): 23/23 RT-PCR+ complex/variant translocations: 8/9 RT-PCR+ no rearrangement of 11, 21, or 22: 6/8 RT-PCR+ | NR | NR | NR
ES (RT-PCR) Gamberi, 2011^17^ 2006–2009 Multinational, not U.S. Fair | Age: NR Female: 73 N: 222 | ES family tumors | Interpretable RT-PCR or FISH: 188/222 RT-PCR +: 144 FISH+: 24 | NR | Tissue quality standards: Inadequate tissue ≤ 1,000 tumor cells, poor RNA quality [A260/280 < 1.6] or negative RT-PCR results FISH: ≥ 100 tumor cell nuclei counted | Required percentage of valid markers: Positive FISH: translocation > 10% of the cell QC standards for assay: RNA integrity: Primers for β-actin. RT-PCR: Positive controls with translocation confirmed by sequencing. Negative controls: normal tissue, other types of tumors, and a water blank
ES (RT-PCR) Lae, 2002^18^ 1992–2000 U.S. only Good | Age: Range: 6–54 Mean: 25 years 0–9: 1 10–24: 14 25–49: 15 50–64: 2 65+: 0 Female: 3% N: 32 | Extraskeletal ES, primitive neuroectodermal tumor, rhabdomyosarcoma, intraabdominal small round cell tumor, intraabdominal carcinoma | 28/29 (Southern blot confirmation) No molecular analysis: 2 | 1/1 | NR
ES (RT-PCR) Lewis, 2007^12^ NR U.S. only Good | Age: Range: 1–26 0–9: 9 10–24: 39 25–49: 2 Female: 15/50 N: 69 (2 cases had multiple tumors) | ES Controls: ES, neuroblastoma, leiomyosarcoma, desmoplastic sarcoma, synovial sarcoma, rhabdomyosarcoma | NR | NR | Failed RNA extraction: 17% 4 had Cp > 35 for housekeeping control gene | QC standards for assay: Two real-time RT-PCR systems employed for detecting transcripts. As a control for cDNA synthesis and sample quality, each sample reverse transcribed and amplified for the housekeeper gene MRPL19
ES (FISH) Mhawech-Fauceglia, 2006^19^ NR U.S. only Good | Age: NR Female: NR N: 58 | ES | 50% | 100% | NR | NR
ES (RT-PCR) Patel 2005^20^ NR U.S. only Good | Age: NR Female: NR N: 42 | Clear cell sarcoma, malignant melanoma | Concordance between duplicate cores (Pearson coefficient): Clear cell sarcoma: 0.99 Malignant melanoma: 0.97 | NR | NR | NR
ES (FISH and RT-PCR) Yamaguchi, 2012^21^ NR Multinational, not U.S. Fair | Age: 10–24: 7 25–49: 13 50–64: 6 65+: 2 NR: 9 Female: 13 N: 37 | ES/primitive neuroectodermal tumor, desmoplastic small round cell tumor, clear cell sarcoma Negative controls: Poorly differentiated synovial sarcoma, alveolar rhabdomyosarcoma, neuroblastoma | RT-PCR compared with FISH: ES/primitive neuroectodermal tumor: 4/6 Desmoplastic small round cell tumor: 6/6 Clear cell sarcoma: 5/5 | RT-PCR compared with FISH: 3/9 | NA | NA

Abbreviations: FISH = fluorescent in situ hybridization; NR = not reported; RT-PCR = reverse transcriptase polymerase chain reaction

Fusion transcripts were detected by both methods in all six cases of desmoplastic small-round-cell tumor (DSRCT) and in five of six cases of clear cell sarcoma.

One good study15 and one fair study4 compared RT-PCR, karyotype, and FISH, although not all tumors were tested with all three tests. In one study,15 standard cytogenetic analysis (G-banded karyotype) was successful in 29 of 74 (39%) cases and identified translocations in 11 of the 29 cases. In the second study,4 a translocation was identified by karyotype in 23 of 40 (58%) of cases. RT-PCR identified fusion transcripts in all cases with a translocation identified by karyotype, plus 4^15^ and 6^4^ additional cases. In the Delattre study,4 FISH identified one translocation not identified by RT-PCR. Barr et al.15 also tested 41 cases for the PAX3-FKHR transcript associated with alveolar rhabdomyosarcoma using RT-PCR and FISH. FISH produced definitive results in 31 cases; RT-PCR results were concordant with FISH in 30 cases. Compared with FISH, the sensitivity of RT-PCR was 92 percent (11/12) and specificity was 100 percent.

Lae et al.18 validated RT-PCR detection of EWS-WT1 fusion transcripts by Southern blot. A fusion transcript was detected in 28 of 30 patients. Southern blot detected one transcript not detected by RT-PCR (RT-PCR sensitivity: 97%). One tumor had no tumor transcript detected by either RT-PCR or Southern blot even though its clinicopathologic and immunohistochemical profile was typical of SRCT.

Lewis et al.12 reported relatively high failure rates for RT-PCR. Sixteen of 69 (23%) samples failed the analysis: 12 (17%) failed RNA extraction and 4 (6%) were excluded because of poor sample quality. Extraction or PCR failure was not associated with sample age.

#### Clinical Validity

Nine studies4, 12, 15–21 examined the clinical validity of genetic tests (RT-PCR, FISH, or karotype) for the diagnosis of ES (Table G-4). Five studies12, 15, 18–20 were rated good, and four were rated fair.4, 16, 17, 21

Four studies,16, 17, 19, 21 two good17, 19 and two fair,16, 21 reported on the sensitivity and specificity of FISH to diagnose ES or other SCRT by detecting specific chromosomal translocations. The sensitivity ranged from 50 percent (19 of 38)19 to 91 percent.16 The two studies rated good reported lower sensitivity of FISH—50 percent19 and 66 percent17—than the two studies rated fair—88 percent21 and 91 percent.16 In all four studies,16, 17, 19, 21 specificity was 100 percent (15/15).

Eight studies4, 12, 15–18, 20, 21 reported on the ability of RT-PCR to diagnosis ES and other SCRTs by detecting fusion transcripts associated with specific tumors. Four studies12, 15, 18, 20 were rated good, and four were rated fair.4, 16, 17, 21 In 7 of the 8 studies, the sensitivity of RT-PCR ranged from 70 percent20 to 93 percent.18 The exception reported RT-PCR sensitivity to be 54 percent.16 As previously noted, the reporting for this study16 was unclear, and the reported sensitivity could not be verified from the data presented in the article. Specificity for RT-PCR ranged from 85 percent16 to 100 percent.4, 12, 17, 20 The quality of the study was not related to the reported sensitivity or specificity.

Table G-4 KQ 3b–3f. Evidence of accuracy of the TOO test in ES

TOO test, Author, year Study Dates, Region | Sample Characteristics | Cancer/tumor types | Sample size | Gold standard (comparison test) | Sensitivity | Specificity
ES (FISH) Mhawech-Fauceglia, 2006^19^ NR U.S. only Good | Age: NR Female: NR N: 58 | ES | 53 | IHC | 19/38 (0.50: assumes 38 is the total number of cases with successful FISH analysis, not number of rearranged, based on information in text) | 15/15 (1.00)
ES (FISH) Yamaguchi, 2012^21^ NR Multinational, not U.S. Fair | Age: 10–24: 7 25–49: 13 50–64: 6 65+: 2 Female: 13 N: 28 | ES/primitive neuroectodermal tumor, desmoplastic small round cell tumor, clear cell sarcoma Negative controls: Poorly differentiated synovial sarcoma, alveolar rhabdomyosarcoma, neuroblastoma | 37 | Clinico-pathological assessment | ES/PNET: 14/16 DSRCT: 6/6 CCS : 5/6 | 0/9
ES (RT-PCR) Barr, 1995^15^ 1988–1993 U.S. only Good | Age: NR Female: NR N: 79 | Alveolar rhabdomyosarcoma, embryonal rhabdomyosarcoma, ES, desmoplastic small round cell tumor, undifferentiated small round cell tumor, other. | Expected positive: 1. Alveolar rhabdomyo-sarcoma=21 2. ES=8 3. Desmo-plastic small round cell tumor=3 Expected negative 4. Embryonal rhabdomyosarcoma=30 5. Undiffer-entiated small round cell tumor=7 6. Other=10 | Clinicopathological assessment | Positives among expected positives 1. 18/21 2. 6/8 3. 3/3 Overall: 27/32 (84%) | Negatives among expected negatives 4. 28/30 5. 5/7 6. 9/10 Overall: 42/47 (89%)
ES (RT-PCR) Bridge, 2006^16^ 2004 U.S. only Fair | Age: NR Female: NR N: 66 | ES/primitive neuroectodermal tumor undifferentiated round cell sarcomas, small cell carcinomas, neuroblastomas, alveolar rhabdomyo-sarcomas, fibrosarcomas, malignant teratoma | N = 67 FISH break apart method N = 66 FISH fusion method N = 43 RT-PCR | Clinico-pathological assessment | FISH break apart: 91% (actual numbers not reported, cannot be calculated from provided data) FISH fusion: 91% RT-PCR: 54% | FISH break apart: 100% FISH fusion: 100% RT-PCR: 85%
ES (RT-PCR) Delattre, 1994^4^ 1993 NR Fair | Age: Range: 1 to 48 Median: 13 Female: NR N: 114 | Osseous ES, atypical ES, peripheral primitive neuroectodermal, not ES tumors, lacking hallmarks of specific disease | 114 | Clinicopathological assessment | 83/87 | Non-ES: 0/12 Undifferen-tiated: 9/15
ES (RT-PCR) Gamberi, 2011^17^ 2006–2009 Multinational, not U.S. Fair | Age: NR Female: 73 N: 222 | ES family tumors | 188 | IHC | 144/156 | SRCT: 0/4 Non-EFT/SRCT: 0/28
ES (RT-PCR) Lae, 2002^18^ 1992–2000 U.S. only Good | Age: Range: 6–54 Mean: 25 years 0–9: 1 10–24: 14 25–49: 15 50–64: 2 65+: 0 Female: 3% N: 32 | Extraskeletal ES, primitive neuroectodermal tumor, rhabdomyosar-coma, intraabdominal small round cell tumor, intraabdominal carcinoma | 32 | Clinico-pathological assessment | RT-PCR = 28/30 (93%) Southern blot hybridization=29/30 (97%) | NR
ES (RT-PCR) Lewis, 2007^12^ NR U.S. only Good | Age: Range: 1–26 0–9: 9 10–24: 39 25–49: 2 Female: 15/50 N: 69 (2 cases had multiple tumors) | ES Controls: ES, neuroblastoma, leiomyosarcoma, desmoplastic sarcoma, synovial sarcoma, rhabdomyosarcoma | ES: 53 non ES: 11 | IHC | 41/50 (82%) | 0/11
ES (RT-PCR) Patel, 2005^20^ NR U.S. only Good | Age: NR Female: NR N: 42 | Clear cell sarcoma, malignant melanoma | Clear cell sarcoma N = 10 Malignant melanoma N = 32 | Known origin | 7/10 (70%) | 0/32 (100%)
ES (RT-PCR) Yamaguchi21, 2012 NR Multinational, not U.S. Fair | Age: 10–24: 7 25–49: 13 50–64: 6 65+: 2 Female: 13 N: 37 | ES/PNET, DSRCT, CCS Negative controls: Poorly differentiated synovial sarcoma, alveolar rhabdomyosarcoma, neuroblastoma | 37 | Clinico-pathological assessment | RT-PCR: ES/PNET: 5/7 DSRCT: 6/6 CCS: 5/5 | 6/9

Abbreviations: CCS =clear cell sarcoma; DSRCT = desmoplastic small-round-cell tumor; EFT =Ewing family tumor; ES = Ewing sarcoma; FISH = fluorescent in situ hybridization; IHC = immunohistochemistry; NA = not applicable; NR = not reported; PNET = primitive neuroectodermal embriogenic tumor; RT-PCR = reverse transcriptase polymerase chain reaction; SRCT = soft tissue small round cell tumors; TOO = tissue of origin

#### Clinical Utility

One study17 rated good reported on the usefulness of molecular genetic tests for the diagnosis of SRCTs. Molecular analysis was informative in 188 of 222 (85%) cases with a presumptive diagnosis of ES. The molecular analysis protocol of RT-PCR analysis followed by FISH in cases that were failed or negative by RT-PCR had a sensitivity of 92 percent and specificity of 100 percent.

### Discussion

This review of genetic tests for the diagnosis of SCRTs is neither complete nor systematic. The literature reviewed here was identified ancillary to our systematic review of genetic or molecular tests for CUP origin. Even this limited review suggests that molecular genetic tests are valuable aids to the challenge of diagnosing SCRTs and differentiating them from other tumors with similar morphology and pathology. Both molecular techniques had good analytic and clinical sensitivity and specificity. Only two studies4, 15 compared molecular analysis to G-banded karyotype, but both demonstrated that the molecular techniques have much higher success and sensitivity. Neither FISH nor RT-PCR was clearly superior. Each technique missed translocations that were identified by the other technique. Although a definite conclusion cannot be made from this review, our results suggest that a combined protocol, such as that used by Gamberi et al.,17 would provide the best sensitivity in clinical practice.

#### References

1 Ambros IM, Ambros PF, Strehl S, et al. MIC2 is a specific marker for Ewing’s sarcoma and peripheral primitive neuroectodermal tumors. Evidence for a common histogenesis of Ewing’s sarcoma and peripheral primitive neuroectodermal tumors from MIC2 expression and specific chromosome aberration. Cancer. Apr. 1. 1991;67(7):1886-1893. [pmid: 1848471].
2 Chen QR, Vansant G, Oades K, et al. Diagnosis of the small round blue cell tumors using multiplex polymerase chain reaction. J Mol Diagn. Feb. 2007;9(1):80-88. [pmid: 17251339].
3 Llombart-Bosch A, Navarro S. Immunohistochemical detection of EWS and FLI-1 proteins in Ewing sarcoma and primitive neuroectodermal tumors: comparative analysis with CD99 (MIC-2) expression. Appl Immunohistochem Mol Morphol. Sep. 2001;9(3):255-260. [pmid: 11556754].
4 Delattre O, Zucman J, Melot T, et al. The Ewing family of tumors--a subgroup of small-round-cell tumors defined by specific chimeric transcripts. N Engl J Med. Aug. 4. 1994;331(5):294-299. [pmid: 8022439].
5 West DC. Ewing sarcoma family of tumors. Curr Opin Oncol. Jul. 2000;12(4):323-329. [pmid: 10888417].
6 Peter M, Mugneret F, Aurias A, et al. An EWS/ERG fusion with a truncated N-terminal domain of EWS in a Ewing’s tumor. Int J Cancer. Jul. 29. 1996;67(3):339-342. [pmid: 8707406].
7 Zucman J, Melot T, Desmaze C, et al. Combinatorial generation of variable fusion proteins in the Ewing family of tumours. EMBO J. Dec. 1993;12(12):4481-4487. [pmid: 8223458].
8 Riley RD, Burchill SA, Abrams KR, et al. A systematic review of molecular and biological markers in tumours of the Ewing’s sarcoma family. Eur J Cancer. Jan. 2003;39(1):19-30. [pmid: 12504654].
9 Esiashvili N, Goodman M, Marcus RB Jr. Changes in incidence and survival of Ewing sarcoma patients over the past 3 decades: Surveillance Epidemiology and End Results data. J Pediatr Hematol Oncol. Jun. 2008;30(6):425-430. [pmid: 18525458].
10 Balamuth NJ, Womer RB. Ewing’s sarcoma. Lancet Oncol. Feb. 2010;11(2):184-192. [pmid: 20152770].
11 Subbiah V, Anderson P, Lazar AJ, et al. Ewing’s sarcoma: standard and experimental treatment options. Curr Treat Options Oncol. Apr. 2009;10(1–2):126-140. [pmid: 19533369].
12 Lewis TB, Coffin CM, Bernard PS. Differentiating Ewing’s sarcoma from other round blue cell tumors using a RT-PCR translocation panel on formalin-fixed paraffin-embedded tissues. Mod Pathol. Mar. 2007;20(3):397-404. [pmid: 17334332].
13 Sorensen PH, Lynch JC, Qualman SJ, et al. PAX3-FKHR and PAX7-FKHR gene fusions are prognostic indicators in alveolar rhabdomyosarcoma: a report from the children’s oncology group. J Clin Oncol. Jun. 1. 2002;20(11):2672-2679. [pmid: 12039929].
14 Ladanyi M, Antonescu CR, Leung DH, et al. Impact of SYT-SSX fusion type on the clinical behavior of synovial sarcoma: a multi-institutional retrospective study of 243 patients. Cancer Res. Jan. 1. 2002;62(1):135-140. [pmid: 11782370].
15 Barr FG, Chatten J, D’Cruz CM, et al. Molecular assays for chromosomal translocations in the diagnosis of pediatric soft tissue sarcomas. JAMA. Feb. 15. 1995;273(7):553-557. [pmid: 7530783].
16 Bridge RS, Rajaram V, Dehner LP, et al. Molecular diagnosis of Ewing sarcoma/primitive neuroectodermal tumor in routinely processed tissue: a comparison of two FISH strategies and RT-PCR in malignant round cell tumors. Mod Pathol. Jan. 2006;19(1):1-8. [pmid: 16258512].
17 Gamberi G, Cocchi S, Benini S, et al. Molecular diagnosis in ewing family tumors the rizzoli experience-222 consecutive cases in four years. J Mol Diagn. 2011;13(3):313-324. [pmid: 21458383].
18 Lae ME, Roche PC, Jin L, et al. Desmoplastic small round cell tumor: a clinicopathologic, immunohistochemical, and molecular study of 32 tumors. Am J Surg Pathol. Jul. 2002;26(7):823-835. [pmid: 12131150].
19 Mhawech-Fauceglia P, Herrmann F, Penetrante R, et al. Diagnostic utility of FLI-1 monoclonal antibody and dual-colour, break-apart probe fluorescence in situ (FISH) analysis in Ewing’s sarcoma/primitive neuroectodermal tumour (EWS/PNET). A comparative study with CD99 and FLI-1 polyclonal antibodies. Histopathology. 2006;49(6):569-575. [pmid: 17163841].
20 Patel RM, Downs-Kelly E, Weiss SW, et al. Dual-color, break-apart fluorescence in situ hybridization for EWS gene rearrangement distinguishes clear cell sarcoma of soft tissue from malignant melanoma. Mod Pathol. Dec. 2005;18(12):1585-1590. [pmid: 16258500].
21 Yamaguchi U, Hasegawa T, Morimoto Y, et al. A practical approach to the clinical diagnosis of Ewing’s sarcoma/primitive neuroectodermal tumour and other small round cell tumours sharing EWS rearrangement using new fluorescence in situ hybridisation probes for EWSR1 on formalin fixed, paraffin wax embedded tissue. J Clin Pathol. Oct. 2005;58(10):1051-1056. [pmid: 16189150].