# Strength of Evidence Assessment Table

Table F-1 Overview of study outcomes

Key Question | Number of Studies | Conclusion | Strength of Evidence
KQ 2. Analytic validity: CancerTypeID | 1 | Only one study that was conducted by manufacturer of test. Limited measures of analytic validity reported and impossible to assess consistency of those measures across studies. | Insufficient
KQ 2. Analytic validity: miRview miRview mets | 4 | Four studies each reported different measures of analytic validity. Impossible to evaluate consistency of reported measures of analytical validity across studies. | Insufficient
KQ 2. Analytic validity: PathworkDx | 3 | Three papers reported measures of analytic validity. There is moderate consistency between studies of interlaboratory reproducibility. The reported precision in these three papers is high. | High
KQ 2. Analytic validity: PathworkDx Endometrial | 1 | One study reported on the analytic validity of a PathworkDx Endometrial test. The reported precision of the test is high, but there is insufficient evidence to assess analytic validity. | Insufficient
KQ 3a. Adherence to Simon guidelines: CancerTypeID | 2 | Report on the development of the algorithm has sufficient detail on development and validation to assess the validity of the process. Development met the Simon^3^ criteria. | High
KQ 3a. Adherence to Simon guidelines: miRview mets | 2 | Report on development of algorithm has sufficient detail on development and validation to assess the validity of the process. Development met the Simon^3^ criteria. | High
KQ 3a. Adherence to Simon guidelines: PathworkDx | 2 | Report on development of algorithm does not have sufficient detail on development and validation to assess the validity of the process. | Low
KQ 3a. Adherence to Simon guidelines: PathworkDX endometrial | 1 | Report on development of algorithm does not have sufficient detail on development and validation to assess the validity of the process. | Low
KQ 3b. Accuracy of the TOO test in classifying the origin and type of tumors of known primary site: CancerTypeID | 7 | Seven studies representing 1,476 tissue samples compared the ability of tests to identify origin of tumor in tissues of known origin. All report accuracy of inclusion. Accuracy of exclusion reported in two studies. | High
KQ 3b. Accuracy of the TOO test in classifying the origin and type of tumors of known primary site: miRview mets | 4 | Two independent studies representing 898 tissue samples tested the ability of the miRview to identify site of origin in tissues of known origin. Accuracies of inclusion and exclusion are reported for both. | High
KQ 3b. Accuracy of the TOO test in classifying the origin and type of tumors of known primary site: PathworkDx | 9 | Nine studies representing 1,247 tissue samples report on the ability of the test to identify the origin of tumor in tissues of known origin. Accuracy of included tissue is reported in all studies. Accuracy of excluded tissues reported in two studies. | High
KQ 4. Percentage of cases for which a TOO test identified a TOO | 17 | Fifteen studies rated fair provided evidence on this question. The ability of the test to identify a TOO was judged using different criteria in different studies. | Moderate
KQ 4. Percentage of CUP cases for which the TOO identified by the test was independently confirmed | 6 | Five studies all rated fair provided evidence for this question. Gold standard varied across studies and precision across studies was moderate. Accuracy ranged from 57% to 100%. | Low
KQ 4: Percentage of CUP cases where TOO modified diagnosis | 6 | Four studies rated fair and one poster rated good provided evidence for this question. Some explored potential changes; others actual changes. The reported percentage of changes ranged from 65% to 81%. Response rates in the survey were fairly low. | Low
KQ 4: Percentage of CUP cases where test was considered clinically useful by physician or researcher | 6 | All studies found test clinically useful in a proportion of cases. Clinical usefulness was measured differently in each study. Wide estimate in the proportion of cases where test was useful. | Low
KQ 4: Change in treatment decisions | 5 | Studies have small samples, varied study designs and measures of effect on treatment decisions, making it difficult to draw conclusions on any of the tests. | Insufficient
KQ 4: Treatment response: Tissue-specific treatment based on TOO test compared with usual treatment for CUP cases | 4 | Small samples, insufficient studies to draw conclusions on any of the tests. Only one study has a control; all others use historical controls. | Insufficient
KQ 4: Change in survival | 5 | Small samples, insufficient studies to draw conclusions on any of the tests. Most use historical controls. | Low
KQ 4: Change in disease progression | 1 | Small samples, insufficient studies to draw conclusions on any of the tests. | Insufficient
KQ 5: Applicability | 22 | Almost all studies included patients age 65 and older and both male and female patients. The studies that reported race included mostly Caucasian patients. | High