# Excluded Articles

## Exclusion Code Key

EXC1= Wrong intervention

EXC2 = Wrong publication type

EXC3 = Wrong study design

EXC4 = No relevant outcomes to Key Questions

BKG = Excluded for BKG

### Excluded at Abstract Stage

1 ASCO-NCI-EORTC immunohistochemistry meta-analysis. 2008. Molecular Markers. hand search.
2 CDKN2A mutations and MC1R variants in Italian patients with single or multiple primary melanoma. Pigm Cell Melanoma R. 2008. 2008/12//;21(6):700+. EXC1.
3 Abstracts from the 2008 Annual Meeting of the American Epilepsy Society. Epilepsia. 2008. 2008/10//;49(s7):1+. EXC1.
4 CLINICAL VIGNETTES. Am J Gastroenterol. 2008. 2008/09//;103(s1):S206. EXC2.
5 COLORECTAL CANCER PREVENTION. Am J Gastroenterol. 2008. 2008/09//;103(s1):S537. EXC1.
6 INFLAMMATORY BOWEL DISEASE. Am J Gastroenterol. 2008. 2008/09//;103(s1):S408. EXC1.
7 Association for Molecular Pathology 2010 Meeting Abstracts. J Mol Diagn. 2010;12(6):854-931. EXC1.
8 Asuragen to Become First Shop to Sell miRNA Dx as Pancreatic Cancer Test to Debut in May | Gene Silencing News | RNAi | GenomeWeb. 2011. http://www.genomeweb.com/rnai/asuragen-become-first-shop-sell-mirna-dx-pancreatic-cancer-test-debut-may-0. EXC1.
9 New genomics sequencing technologies a review of the regulatory and policy issues. 2011. https://www.kcl.ac.uk/content/1/c6/03/01/49/HealthCanadamicroarraysreport.pdf. EXC1.
10 Abbrederis K, Lorenzen S, Rothling N, et al. Chemotherapy-induced nausea and vomiting in the treatment of gastrointestinal tumors and secondary prophylaxis with aprepitant. Onkologie. 2009:30-34. EXC1. [pmid: 19209016].
11 Abdulkareem FB, Rotimi O. Immunophenotypical categorization of omental and liver metastatic tumours in Lagos, Nigeria. Nig Q J Hosp Med. Oct-Dec. 2008;18(4):198-201. EXC1. [pmid: 19391319].
12 Abi-Habib RJ, Singh R, Liu S, et al. A urokinase-activated recombinant anthrax toxin is selectively cytotoxic to many human tumor cell types. Mol Cancer Ther. Oct. 2006;5(10):2556-2562. EXC1. [pmid: 17041100].
13 Acevedo P, Castro V. Gene-expression profiling and cancer of an unknown primary origin. Commun Oncol. 2008;5:590-592. hand search, EXC2.
14 Adorjan P, Distler J, Lipscher E, et al. Tumour class prediction and discovery by microarray-based DNA methylation analysis. Nucleic Acids Res. Mar. 1. 2002;30(5):e21. EXC1. [pmid: 11861926].
15 Albitar M, Potts SJ, Giles FJ, et al. Proteomic-based prediction of clinical behavior in adult acute lymphoblastic leukemia. Cancer. Apr. 1. 2006;106(7):1587-1594. EXC1. [pmid: 16518825].
16 Ambrosini V, Rubello D, Nanni C, et al. Additional value of hybrid PET/CT fusion imaging vs. conventional CT scan alone in the staging and management of patients with malignant pleural mesothelioma. Nuclear medicine review. Central & Eastern Europe: journal of Bulgarian, Czech, Macedonian, Polish, Romanian, Russian, Slovak, Yugoslav societies of nuclear medicine and Ukrainian Society of Radiology. 2005:111-115. EXC1.
17 Amundson SA, Do KT, Vinikoor LC, et al. Integrating global gene expression and radiation survival parameters across the 60 cell lines of the National Cancer Institute Anticancer Drug Screen. Cancer Res. Jan. 15. 2008;68(2):415-424. EXC1. [pmid: 18199535].
18 Anderson GG, Weiss LM. A meta-analysis of the use of IHC testing in metastatic disease: the need for integration of new technologies. ASCO-NCI-EORTC Annual Meeting on Molecular Markers in Cancer. 2008 Oct 30 - Nov 1. Hollywood, FL. hand search, EXC2.
19 Anderson GG, Weiss LM. Determining tissue of origin for metastatic cancers: meta-analysis and literature review of immunohistochemistry performance. Appl Immunohistochem Mol Morphol. Jan. 2010;18(1):3-8. EXC1. [pmid: 19550296].
20 Andersson A, Ritz C, Lindgren D, et al. Microarray-based classification of a consecutive series of 121 childhood acute leukemias: prediction of leukemic and genetic subtype as well as of minimal residual disease status. Leukemia. Jun. 2007;21(6):1198-1203. EXC1. [pmid: 17410184].
21 Andrieux A, Switsers O, Chajari MH, et al. Clinical impact of fluorine-18 fluorodeoxyglucose positron emission tomography in cancer patients. A comparative study between dedicated camera and dual-head coincidence gamma camera. Q J Nucl Med Mol Imaging. 2006:68-77. EXC1. [pmid: 16557206].
22 Aparicio A, Tzelepi V, Araujo JC, et al. Neuroendocrine prostate cancer xenografts with large-cell and small-cell features derived from a single patient’s tumor: morphological, immunohistochemical, and gene expression profiles. Prostate. Jun. 1. 2011;71(8):846-856. EXC1. [pmid: 21456067].
23 Arvand A, Denny CT. Biology of EWS/ETS fusions in Ewing’s family tumors. Oncogene. Sep. 10. 2001;20(40):5747-5754. hand search, EXC2. [pmid: 11607824].
24 Ashktorab H, Brim H, Al-Riyami M, et al. Sporadic colon cancer: Mismatch repair immunohistochemistry and microsatellite instability in omani subjects. Dig Dis Sci. Oct. 2008;53(10):2723-2731. EXC1. [pmid: 18299982].
25 Baehring JM, Androudi S, Longtine JJ, et al. Analysis of clonal immunoglobulin heavy chain rearrangements in ocular lymphoma. Cancer. Aug. 1. 2005;104(3):591-597. EXC1. [pmid: 15973665].
26 Balducci E, Azzarello G, Valori L, et al. A new nested primer pair improves the specificity of CK-19 mRNA detection by RT-PCR in occult breast cancer cells. Int J Biol Markers. Jan-Mar. 2005;20(1):28-33. EXC1. [pmid: 15832770].
27 Balogh K, Hunyady L, Illyes G, et al. Unusual presentation of multiple endocrine neoplasia type 1 in a young woman with a novel mutation of the MEN1 gene. J Hum Genet. 2004. 2004/07//;49(7):380. EXC1.
28 Bankhead A 3rd, Magnuson NS, Heckendorn RB. Cellular automaton simulation examining progenitor hierarchy structure effects on mammary ductal carcinoma in situ. J Theor Biol. Jun. 7. 2007;246(3):491-498. EXC1. [pmid: 17335852].
29 Barnes A, Bridge P, Green J, et al. Impact of gender and parent-of-origin on phenotypic expression of hereditary non-polyposis colon cancer (HNPCC) in 12 Newfoundland families with a founder MSH2 mutation. Am J Hum Gene. 2000. 2000/10//;67(4):17. EXC1.
30 Barresi V, Cerasoli S, Paioli G, et al. Caveolin-1 in meningiomas: expression and clinico-pathological correlations. Acta Neuropathol. Nov. 2006;112(5):617-626. EXC1. [pmid: 16850311].
31 Bates S. Progress towards personalized medicine. 2010. http://www.sciencedirect.com/science?_ob=GatewayURL&_origin=ScienceSearch&_method=citationSearch&_piikey=S1359644609003730&_version=1&_returnURL=http%3A%2F%2Fwww.scirus.com%2Fsrsapp%2F&md5=615dd8dbcff3223a30dabac35ece164c15. EXC1.
32 Becker B, Roesch A, Hafner C, et al. Discrimination of melanocytic tumors by cDNA array hybridization of tissues prepared by laser pressure catapulting. J Invest Dermatol. Feb. 2004;122(2):361-368. EXC1. [pmid: 15009717].
33 Becker SH. Identifying tumors of uncertain origin. Adv Admin Lab. 2006;15(11):58. EXC2.
34 Bedikian AY, Papadopoulos NE, Kim KB, et al. A pilot study with vincristine sulfate liposome infusion in patients with metastatic melanoma. Melanoma Res. 2008:400-404. EXC1. [pmid: 19011511].
35 Bender RA, Erlander MG. Molecular classification of unknown primary cancer. Semin Oncol. Feb. 2009;36(1):38-43. EXC4. [pmid: 19179186].
36 Benjamin H, Lebanony D, Rosenwald S, et al. A diagnostic assay based on microRNA expression accurately identifies malignant pleural mesothelioma. J Mol Diagn. Nov. 2010;12(6):771-779. EXC1. [pmid: 20864637].
37 Berg T, Kalsaas A-H, Buechner J, et al. Ewing sarcoma–peripheral neuroectodermal tumor of the kidney with a FUS–ERG fusion transcript. Cancer Genet Cytogenet. 2009;194(1):53-57. EXC2, EXC3. [pmid: 19737655].
38 Bergamaschi A, Kim YH, Kwei KA, et al. CAMK1D amplification implicated in epithelial-mesenchymal transition in basal-like breast cancer. Mol Oncol. Dec. 2008;2(4):327-339. EXC1. [pmid: 19383354].
39 Bergers G, Brekken R, McMahon G, et al. Matrix metalloproteinase-9 triggers the angiogenic switch during carcinogenesis. Nat Cell Biol. Oct. 2000;2(10):737-744. EXC1. [pmid: 11025665].
40 Bhargava R, Dabbs DJ. Chapter 8 - Immunohistology of Metastatic Carcinomas of Unknown Primary. Diagnosis Immunohistochemistry. 2011:206-255. EXC1, EXC2.
41 Bhatti P, Kampa D, Alexander BH, et al. Blood spots as an alternative to whole blood collection and the effect of a small monetary incentive to increase participation in genetic association studies. BMC Med Res Methodol. 2009:76. EXC1. [pmid: 19912630].
42 Bilke S, Chen QR, Whiteford CC, et al. Detection of low level genomic alterations by comparative genomic hybridization based on cDNA micro-arrays. Bioinformatics. Apr. 1. 2005;21(7):1138-1145. EXC1. [pmid: 15539449].
43 Binder G, Weber S, Ehrismann M, et al. Effects of dehydroepiandrosterone therapy on pubic hair growth and psychological well-being in adolescent girls and young women with central adrenal insufficiency: a double-blind, randomized, placebo-controlled phase III trial. J Clin Endocrinol Metab. 2009:1182-1190. EXC1. [pmid: 19126625].
44 Bloom G, Yang IV, Boulware D, et al. Multi-platform, multi-site, microarray-based human tumor classification. Am J Pathol. Jan. 2004;164(1):9-16. EXC1. [pmid: 14695313].
45 BlueCross BlueShield A. Special report: recent developments in prostate cancer genetics and genetic testing (Structured abstract). Chicago IL. Blue Cross Blue Shield Association (BCBS). 2008. EXC1.
46 Bonneterre J, Buzdar A, Nabholtz JM, et al. Anastrozole is superior to tamoxifen as first-line therapy in hormone receptor positive advanced breast carcinoma. Cancer. 2001:2247-2258. EXC1. [pmid: 11745278].
47 Bonneterre J, Thürlimann B, Robertson JF, et al. Anastrozole versus tamoxifen as first-line therapy for advanced breast cancer in 668 postmenopausal women: results of the Tamoxifen or Arimidex Randomized Group Efficacy and Tolerability study. J Clin Oncol. 2000:3748-3757. EXC1. [pmid: 11078487].
48 Bowen DJ, Ludman E, Press N, et al. Achieving utility with family history: Colorectal cancer risk. Am J Prev Med. February. 2003;24(2):177-182. EXC1. [pmid: 12568824].
49 Braeuer RR, Zigler M, Villares GJ, et al. Transcriptional control of melanoma metastasis: the importance of the tumor microenvironment. Semin Cancer Biol. Apr. 2011;21(2):83-88. EXC1. [pmid: 21147226].
50 Bridge RS, Rajaram V, Dehner LP, et al. Molecular diagnosis of Ewing sarcoma/primitive neuroectodermal tumor in routinely processed tissue: a comparison of two FISH strategies and RT-PCR in malignant round cell tumors. Mod Pathol. Jan. 2006;19(1):1-8. EXC1. [pmid: 16258512].
51 Bridgewater J, van Laar R, Floore A, et al. Gene expression profiling may improve diagnosis in patients with carcinoma of unknown primary. Br J Cancer. Apr. 22. 2008;98(8):1425-1430. EXC. [pmid: 18414470].
52 Brooks AD, Ramirez T, Toh U, et al. The proteasome inhibitor bortezomib (Velcade) sensitizes some human tumor cells to Apo2L/TRAIL-mediated apoptosis. Ann N Y Acad Sci. Nov. 2005;1059:160-167. EXC1. [pmid: 16382051].
53 Buhr HJ, Grone J, Staub E. Predicting the site of origin of tumors by a gene expression signature derived from normal tissues. Oncogene. 2010. 2010/08/05/;29(31)4485+. EXC.
54 Büntzel J, Riesenbeck D, Glatzel M, et al. Limited effects of selenium substitution in the prevention of radiation-associated toxicities. results of a randomized study in head and neck cancer patients. Anticancer Res. 2010:1829-1832. EXC1. [pmid: 20592387].
55 Bura E, Pfeiffer RM. Graphical methods for class prediction using dimension reduction techniques on DNA microarray data. Bioinformatics. Jul. 1. 2003;19(10):1252-1258. EXC1. [pmid: 12835269].
56 Bussey KJ, Lawce HJ, Himoe E, et al. SNRPN methylation patterns in germ cell tumors as a reflection of primordial germ cell development. Genes Chromosom Cancer. Dec. 2001;32(4):342-352. EXC1. [pmid: 11746975].
57 Butler PC, Potter GA. Non-haematological solid tumours as surrogate granulocytes: a possible mechanism for metastatic spread. Med Hypotheses. May. 2001;56(5):625-628. EXC1. [pmid: 11388779].
58 Buturovic LJ. On the optimal number of gene expression mMarkers for tissue of origin cancer diagnostics. Annual meeting for the American Association for Cancer Research. 2007 September 17–20. Atlanta, GA. B4. hand search.
59 Buzdar A, Douma J, Davidson N, et al. Phase III, multicenter, double-blind, randomized study of letrozole, an aromatase inhibitor, for advanced breast cancer versus megestrol acetate. J Clin Oncol. 2001:3357-3366. EXC1. [pmid: 11454883].
60 Cantin J, Chappuis PO, Deschenes J, et al. Prevalence of founder BRCA1 and BRCA2 mutations in French Canadian women with breast cancer unselected for age or family history. Am J Hum Gene. 2000. 2000/10//;67(4):85. EXC1.
61 Capes-Davis A, Theodosopoulos G, Atkin I, et al. Check your cultures! A list of cross-contaminated or misidentified cell lines. Int J Cancer. Jul. 1. 2010;127(1):1-8. EXC1. [pmid: 20143388].
62 Carl-McGrath S, Ebert MP, Lendeckel U, et al. Expression of the local angiotensin II system in gastric cancer may facilitate lymphatic invasion and nodal spread. Cancer Biol Ther. Aug. 2007;6(8):1218-1226. EXC1. [pmid: 18059164].
63 Carter BZ, Kim TK, Mak DH, et al. AML progenitor/stem cells overexpress XIAP and are sensitive to the small molecular XIAP inhibitor 1396-11. Blood. Nov. 16. 2006;108(11, Part 1):730A-731A. EXC1.
64 Carter J, Hogan RE. Sunday, December 3, 2006Poster Session II7:30 a.m.-4:30 pm. Epilepsia. 2006. 2006/10//;47(s4)119+. EXC1.
65 Centeno BA, Bloom G, Chen DT, et al. Hybrid model integrating immunohistochemistry and expression profiling for the classification of carcinomas of unknown primary site. J Mol Diagn. Jul. 2010;12(4):476-486. EXC1. [pmid: 20558571].
66 Cerezo L, Raboso E, Ballesteros AI. Unknown primary cancer of the head and neck: a multidisciplinary approach. Clin Transl Oncol. Feb. 2011;13(2):88-97. EXC1. [pmid: 21324796].
67 Chajut A, Aharonov R, Rosenwald S, et al. A second generation microRNA-based assay for diagnosing tumor tissue origin. ASCO. 2011. hand search.
68 Chang JC, Hilsenbeck SG, Fuqua SA. Genomic approaches in the management and treatment of breast cancer. Br J Cancer. Feb. 28. 2005;92(4):618-624. EXC1. [pmid: 15714204].
69 Chen HY, Chiang CK, Wang HH, et al. Cognitive-behavioral therapy for sleep disturbance in patients undergoing peritoneal dialysis: a pilot randomized controlled trial. Am J Kidney Dis. 2008:314-323. EXC1. [pmid: 18511165].
70 Chen T, Yan W, Wells RG, et al. Novel inactivating mutations of transforming growth factor-beta type I receptor gene in head-and-neck cancer metastases. Int J Cancer. Sep. 1. 2001;93(5):653-661. EXC1. [pmid: 11477574].
71 Chen YT, Scanlan MJ, Venditti CA, et al. Identification of cancer/testis-antigen genes by massively parallel signature sequencing. Proc Natl Acad Sci U S A. May. 31. 2005;102(22):7940-7945. EXC1. [pmid: 15905330].
72 A gene expression-based assay for identifying tissue of origin: application to metastatic lesions in the brain. Annual meeting of the Society for Neuro-Oncology. 2007. Dallas, TX. Abstract GE-15. EXC1.
73 Chi S, Huang S, Li C, et al. Activation of the hedgehog pathway in a subset of lung cancers. Cancer Lett. 2006:53-60. EXC1. [pmid: 16446029].
74 Chin L, Gray JW. Translating insights from the cancer genome into clinical practice. Nature. Apr. 3. 2008;452(7187):553-563. EXC1. [pmid: 18385729].
75 Cho JH, Lee D, Park JH, et al. Optimal approach for classification of acute leukemia subtypes based on gene expression data. Biotechnol Prog. Jul-Aug. 2002;18(4):847-854. EXC1. [pmid: 12153320].
76 Choi KC, Kang SK, Nathwani PS, et al. Differential expression of activin/inhibin subunit and activin receptor mRNAs in normal and neoplastic ovarian surface epithelium (OSE). Mol Cell Endocrinol. Mar. 28. 2001;174(1–2):99-110. EXC1. [pmid: 11306176].
77 Chorost MI, McKinley B, Tschoi M, et al. The management of the unknown primary. J Am Coll Surg. Dec. 2001;193(6):666-677. EXC2. [pmid: 11768684].
78 Christensen BC, Marsit CJ, Houseman EA, et al. Differentiation of lung adenocarcinoma, pleural mesothelioma, and nonmalignant pulmonary tissues using DNA methylation profiles. Cancer Res. Aug. 1. 2009;69(15):6315-6321. EXC1. [pmid: 19638575].
79 Christensen JH, Abildgaard N, Plesner T, et al. Interphase fluorescence in situ hybridization in multiple myeloma and monoclonal gammopathy of undetermined significance without and with positive plasma cell identification: analysis of 192 cases from the Region of Southern Denmark. Cancer Genet Cytogenet. Apr. 15. 2007;174(2):89-99. EXC1. [pmid: 17452249].
80 Chu F, Wang L. Applications of support vector machines to cancer classification with microarray data. Int J Neural Syst. Dec. 2005;15(6):475-484. EXC1. [pmid: 16385636].
81 Chuang LY, Yang CS, Li JC, et al. Chaotic genetic algorithm for gene selection and classification problems. OMICS. Oct. 2009;13(5):407-420. BKG, EXC1. [pmid: 19594377].
82 Chun HW, Tsuruoka Y, Kim JD, et al. Automatic recognition of topic-classified relations between prostate cancer and genes using MEDLINE abstracts. BMC Bioinformatics. Suppl 3. 2006;7:S4. EXC1. [pmid: 17134477].
83 Claes K, Poppe B, Coene I, et al. BRCA1 and BRCA2 germline mutation spectrum and frequencies in Belgian breast/ovarian cancer families. Br J Cancer. March. 22. 2004;90(6):1244-1251. EXC1. [pmid: 15026808].
84 Coenen MJ, Ploeg M, Schijvenaars MM, et al. Allelic imbalance analysis using a single-nucleotide polymorphism microarray for the detection of bladder cancer recurrence. Clin Cancer Res. Dec. 15. 2008;14(24):8198-8204. EXC1. [pmid: 19088036].
85 Color SG II, Buunen M, Bonjer HJ, et al. COLOR II. A randomized clinical trial comparing laparoscopic and open surgery for rectal cancer. Dan Med Bull. 2009:89-91. EXC1. [pmid: 19486621].
86 Coppe JP, Itahana Y, Moore DH, et al. Id-1 and Id-2 proteins as molecular markers for human prostate cancer progression. Clin Cancer Res. Mar. 15. 2004;10(6):2044-2051. EXC1. [pmid: 15041724].
87 Corbett TH, White K, Polin L, et al. Discovery and preclinical antitumor efficacy evaluations of LY32262 and LY33169. Invest New Drugs. Feb. 2003;21(1):33-45. EXC1. [pmid: 12795528].
88 Cornelissen B, Kersemans V, McLarty K, et al. In vivo monitoring of intranuclear p27(kip1) protein expression in breast cancer cells during trastuzumab (Herceptin) therapy. Nucl Med Biol. Oct. 2009;36(7):811-819. EXC1. [pmid: 19720293].
89 Cornely OA, Bethe U, Seifert H, et al. A randomized monocentric trial in febrile neutropenic patients: ceftriaxone and gentamicin vs cefepime and gentamicin. Ann Hematol. 2002:37-43. EXC1. [pmid: 11807634].
90 Courneya KS, Jones LW, Peddle CJ, et al. Effects of aerobic exercise training in anemic cancer patients receiving darbepoetin alfa: a randomized controlled trial. Oncologist. 2008:1012-1020. EXC1. [pmid: 18779540].
91 Coussens LM, Tinkle CL, Hanahan D, et al. MMP-9 supplied by bone marrow-derived cells contributes to skin carcinogenesis. Cell. Oct. 27. 2000;103(3):481-4890. EXC1. [pmid: 11081634].
92 Cozzio A, Passegue E, Ayton PM, et al. Similar MLL-associated leukemias arising from self-renewing stem cells and short-lived myeloid progenitors. Genes Dev. Dec. 15. 2003;17(24):3029-3035. EXC1. [pmid: 14701873].
93 Cummings SD, Ryu B, Samuels MA, et al. Id1 delays senescence of primary human melanocytes. Mol Carcinog. Sep. 2008;47(9):653-659. EXC1. [pmid: 18240291].
94 Cuzick J, Sestak I, Pinder SE, et al. Effect of tamoxifen and radiotherapy in women with locally excised ductal carcinoma in situ: long-term results from the UK/ANZ DCIS trial. Lancet oncol. 2011:21-29. EXC1. [pmid: 21145284].
95 Dano K, Behrendt N, Hoyer-Hansen G, et al. Plasminogen activation and cancer. Thromb Haemost. Apr. 2005;93(4):676-681. EXC1. [pmid: 15841311].
96 Dansonka-Mieszkowska A, Ludwig AH, Kraszewska E, et al. Geographical variations in TP53 mutational spectrum in ovarian carcinomas. Ann Hum Genet. Sep. 2006;70(Pt 5):594-604. EXC1. [pmid: 16907706].
97 De Cicco C, Trifirò G, Intra M, et al. Optimised nuclear medicine method for tumour marking and sentinel node detection in occult primary breast lesions. Eur J Nucl Med Molec Imaging. 2004:349-354. EXC1. [pmid: 14647985].
98 Delattre O, Zucman J, Melot T, et al. The Ewing family of tumors--a subgroup of small-round-cell tumors defined by specific chimeric transcripts. N Engl J Med. Aug. 4. 1994;331(5):294-299. hand search, EXC4. [pmid: 8022439].
99 Delgado-Bolton RC, Fernandez-Perez C, Gonzalez-Mate A, et al. Meta-analysis of the performance of 18F-FDG PET in primary tumor detection in unknown primary tumors (Structured abstract). J Nucl Med. 2003:1301-1314. EXC1. [pmid: 12902422].
100 Dennis JL, Hvidsten TR, Wit EC, et al. Markers of adenocarcinoma characteristic of the site of origin: development of a diagnostic algorithm. Clin Cancer Res. May. 15. 2005;11(10):3766-3772. EXC1. [pmid: 15897574].
101 Dennis JL, Oien KA. Hunting the primary: novel strategies for defining the origin of tumours. J Pathol. Jan. 2005;205(2):236-247. EXC1. [pmid: 15641019].
102 Dennis JL, Vass JK, Wit EC, et al. Identification from public data of molecular markers of adenocarcinoma characteristic of the site of origin. Cancer Res. Nov. 1. 2002;62(21):5999-6005. EXC1. [pmid: 12414618].
103 Devries S, Nyante S, Korkola J, et al. Array-based comparative genomic hybridization from formalin-fixed, paraffin-embedded breast tumors. J Mol Diagn. Feb. 2005;7(1):65-71. EXC1. [pmid: 15681476].
104 Dillon BJ, Prieto VG, Curley SA, et al. Incidence and distribution of argininosuccinate synthetase deficiency in human cancers: a method for identifying cancers sensitive to arginine deprivation. Cancer. Feb. 15. 2004;100(4):826-833. EXC1. [pmid: 14770441].
105 Ding Y, Wang G, Ling MT, et al. Significance of Id-1 up-regulation and its association with EGFR in bladder cancer cell invasion. Int J Oncol. Apr. 2006;28(4):847-854. EXC1. [pmid: 16525633].
106 Dixon JM, Nicholson RI, Robertson JFR, et al. Comparison of the short-term biological effects of fulvestrant (ICI 182,780) with tamoxifen in postmenopausal women with primary breast cancer. 2nd European Breast Cancer Conference. 2000. EXC1.
107 Dong MJ, Zhao K, Lin XT, et al. Role of fluorodeoxyglucose-PET versus fluorodeoxyglucose-PET/computed tomography in detection of unknown primary tumor: a meta-analysis of the literature (Structured abstract). Nucl Med Commun. 2008:791-802. EXC1. [pmid: 18677207].
108 Dova L, Golfinopoulos V, Pentheroudakis G, et al. Systemic dissemination in cancer of unknown primary is independent of mutational inactivation of the KiSS-1 metastasis-suppressor gene. Pathol Oncol Res. Sep. 2008;14(3):239-241. EXC1. [pmid: 18351443].
109 Dova L, Pentheroudakis G, Georgiou I, et al. Global profiling of EGFR gene mutation, amplification, regulation and tissue protein expression in unknown primary carcinomas: to target or not to target?. Clin Exp Metastasis. 2007;24(2):79-86. EXC1. [pmid: 17390112].
110 Dova L, Pentheroudakis G, Golfinopoulos V, et al. Targeting c-KIT, PDGFR in cancer of unknown primary: a screening study for molecular markers of benefit. J Cancer Res Clin Oncol. Jun. 2008;134(6):697-704. EXC1. [pmid: 18064489].
111 Dowell JE, Garrett AM, Shyr Y, et al. A randomized Phase II trial in patients with carcinoma of an unknown primary site. Cancer. 2001:592-597. EXC1. [pmid: 11169943].
112 Dowsett M, Cuzick J, Wale C, et al. Prediction of risk of distant recurrence using the 21-gene recurrence score in node-negative and node-positive postmenopausal patients with breast cancer treated with anastrozole or tamoxifen: a TransATAC study. J Clin Oncol. 2010:1829-1834. EXC1. [pmid: 20212256].
113 Driscoll JJ, Gauerke S. Hidradenocarcinomas: a brief review and future directions. Arch Pathol Lab Med. 2010. 2010/05//;134(5)781. EXC1.
114 Dudoit S, Fridlyand J. A prediction-based resampling method for estimating the number of clusters in a dataset. Genome Biol. Jun. 25. 2002;3(7). RESEARCH0036. EXC1. [pmid: 12184810].
115 Duenwald S, Zhou M, Wang Y, et al. Development of a microarray platform for FFPET profiling: application to the classification of human tumors. J Transl Med. 2009;7:65. EXC1. [pmid: 19638234].
116 Duffy MJ, O’Donovan N, Crown J. Use of molecular markers for predicting therapy response in cancer patients. Cancer Treat Rev. Apr. 2011;37(2):151-159. EXC1. [pmid: 20685042].
117 Dyrskjot L, Thykjaer T, Kruhoffer M, et al. Identifying distinct classes of bladder carcinoma using microarrays. Nat Genet. Jan. 2003;33(1):90-96. EXC1. [pmid: 12469123].
118 Eleutherakis-Papaiakovou E, Kostis E, Migkou M, et al. Prophylactic antibiotics for the prevention of neutropenic fever in patients undergoing autologous stem-cell transplantation: results of a single institution, randomized phase 2 trial. Am J Hematol. 2010:863-867. EXC1. [pmid: 20882526].
119 Ellis MJ, Coop A, Singh B, et al. Letrozole is more effective neoadjuvant endocrine therapy than tamoxifen for ErbB-1- and/or ErbB-2-positive, estrogen receptor-positive primary breast cancer: evidence from a phase III randomized trial. J Clin Oncol. 2001:3808-3816. EXC1. [pmid: 11559718].
120 Ellison G, Klinowska T, Westwood RF, et al. Further evidence to support the melanocytic origin of MDA-MB-435. Mol Pathol. Oct. 2002;55(5):294-299. EXC1. [pmid: 12354931].
121 Emmons R, Morris GJ. Readers’ responses to "Cancer of unknown primary site: advances in diagnostics". Semin Oncol. Dec. 2010;37(6):555. EXC4. [pmid: 21167373].
122 Enderling H, Chaplain MA, Hahnfeldt P. Quantitative modeling of tumor dynamics and radiotherapy. Acta Biotheor. Dec. 2010;58(4):341-353. EXC1. [pmid: 20658170].
123 Endoh Y, Tamura G, Kato N, et al. Apocrine adenosis of the breast: clonal evidence of neoplasia. Histopathology. Mar. 2001;38(3):221-224. EXC1. [pmid: 11260302].
124 Erdag G, Meck JM, Meloni-Ehrig A, et al. Long-term persistence of nonpathogenic clonal chromosome abnormalities in donor hematopoietic cells after allogeneic stem cell transplantation. Cancer Genet Cytogenet. 2009;190(2):125-130. EXC1. [pmid: 19380032].
125 Erlander MG. Molecular Classification of Cancer: Implications for Carcinoma of Unknown Primary. United States and Canadian Academy of Pathology meeting, AMP companion meeting. 2007. March. 25. hand search, EXC2.
126 Molecular Classification of Tumor of Unknown Origin by Gene-Expression from Fixed Paraffin Embedded Tissue. American Society of Clinical Oncology. 2004. June. hand search, EXC3.
127 Ertekin MV, Koç M, Karslioglu I, et al. Zinc sulfate in the prevention of radiation-induced oropharyngeal mucositis: a prospective, placebo-controlled, randomized study. Int J Radiat Oncol Biol Phys. 2004:167-174. EXC1. [pmid: 14697435].
128 Eschrich S, Zhang H, Zhao H, et al. Systems biology modeling of the radiation sensitivity network: a biomarker discovery platform. Int J Radiat Oncol Biol Phys. Oct. 1. 2009;75(2):497-505. EXC1. [pmid: 19735874].
129 Eschrich SA, Pramana J, Zhang H, et al. A gene expression model of intrinsic tumor radiosensitivity: prediction of response and prognosis after chemoradiation. Int J Radiat Oncol Biol Phys. Oct. 1. 2009;75(2):489-496. EXC1. [pmid: 19735873].
130 Evans JS, Ford BM, Balmana J, et al. Factors predicting willingness to participate in cancer genetic epidemiologic research [abstract]. J Clin Oncol. 2005:529s. EXC1.
131 Fabbri M. miRNAs as molecular biomarkers of cancer. Expert Rev Mol Diagn. May. 2010;10(4):435-444. EXC1. [pmid: 20465498].
132 Fagerberg L, Stromberg S, El-Obeid A, et al. Large-scale protein profiling in human cell lines using antibody-based proteomics. J Proteome Res. Sep. 2. 2011;10(9):4066-4075. EXC1. [pmid: 21726073].
133 Faiss S, Pape UF, Böhmig M, et al. Prospective, randomized, multicenter trial on the antiproliferative effect of lanreotide, interferon alfa, and their combination for therapy of metastatic neuroendocrine gastroenteropancreatic tumors--the International Lanreotide and Interferon Alfa Study Group. J Clin Oncol. 2003:2689-2696. EXC1. [pmid: 12860945].
134 Febbo PG, Kantoff PW. Noise and bias in microarray analysis of tumor specimens. J Clin Oncol. Aug. 10. 2006;24(23):3719-3721. EXC1. [pmid: 16822841].
135 Feng Q, Li P, Salamanca C, et al. Caspase-1alpha is down-regulated in human ovarian cancer cells and the overexpression of caspase-1alpha induces apoptosis. Cancer Res. Oct. 1. 2005;65(19):8591-8596. EXC1. [pmid: 16204022].
136 Ferracin M, Pedriali M, Veronese A, et al. MicroRNA profiling for the identification of cancers with unknown primary tissue-of-origin. J Pathol. Sep. 2011;225(1):43-53. EXC1. [pmid: 21630269].
137 Ferracin M, Veronese A, Negrini M. Micromarkers: miRNAs in cancer diagnosis and prognosis. Expert Rev Mol Diagn. Apr. 2010;10(3):297-308. EXC1. [pmid: 20370587].
138 Figer A, Irmin L, Geva R, et al. The rate of the 6174delT founder Jewish mutation in BRCA2 in patients with non-colonic gastrointestinal tract tumours in Israel. Br J Cancer. February. 2001;84(4):478-481. EXC1. [pmid: 11207041].
139 Fjøsne HE, Jacobsen AB, Lundgren S, et al. Adjuvant cyclic Tamoxifen and Megestrol acetate treatment in postmenopausal breast cancer patients--longterm follow-up. Eur J Surg Oncol. 2008:6-12. EXC1. [pmid: 17881183].
140 Ford BM, Evans JS, Stoffel EM, et al. Factors associated with enrollment in cancer genetics research. Cancer Epidemiol Biomarkers Prev. 2006:1355-1359. EXC1. [pmid: 16835336].
141 Franovic A, Holterman CE, Payette J, et al. Human cancers converge at the HIF-2alpha oncogenic axis. Proc Natl Acad Sci U S A. Dec. 15. 2009;106(50):21306-21311. EXC1. [pmid: 19955413].
142 Frohling S, Dohner H. Chromosomal abnormalities in cancer. N Engl J Med. Aug. 14. 2008;359(7):722-734. EXC1. [pmid: 18703475].
143 Fu R, Gartlehner G, Grant M, et al. Conducting Quantitative Synthesis When Comparing Medical Interventions: AHRQ and the Effective Health Care Program. 2008. EXC1. [pmid: 21433407].
144 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1187-1197. EXC1. [pmid: 21477993].
145 Fu R, Harris EL, Huffman LH, et al. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: systematic evidence review for the U.S. preventive services task force. Ann Intern Med. 2005. 2005/09/06/:362+. EXC1.
146 Fu WJ, Carroll RJ, Wang S. Estimating misclassification error with small samples via bootstrap cross-validation. Bioinformatics. May. 1. 2005;21(9):1979-1986. EXC1. [pmid: 15691862].
147 Futschik ME, Sullivan M, Reeve A, et al. Prediction of clinical behaviour and treatment for cancers. Appl Bioinformatics. 2003;2(3 Suppl):S53-S58. EXC1. [pmid: 15130817].
148 Gamberger D, Lavrac N, Zelezny F, et al. Induction of comprehensible models for gene expression datasets by subgroup discovery methodology. J Biomed Inform. Aug. 2004;37(4):269-284. EXC1. [pmid: 15465480].
149 Gandemer V, de Tayrac M, Mosser J, et al. Prognostic signature of ALL blasts at diagnosis: what can we really find?. Leuk Res. Sep. 2007;31(9):1317-1319. EXC1. [pmid: 17113638].
150 Garcea G, Lloyd T, Steward WP, et al. Differences in attitudes between patients with primary colorectal cancer and patients with secondary colorectal cancer: is it reflected in their willingness to participate in drug trials?. Eur J Cancer Care. 2005:166-170. EXC1.
151 Gardner LJ, Ayala AG, Monforte HL, et al. Ewing sarcoma/peripheral primitive neuroectodermal tumor: adult abdominal tumors with an Ewing sarcoma gene rearrangement demonstrated by fluorescence in situ hybridization in paraffin sections. Appl Immunohistochem Mol Morphol. Jun. 2004;12(2):160-165. EXC2. [pmid: 15354743].
152 Garraway LA, Weir BA, Zhao X, et al. "Lineage addiction" in human cancer: lessons from integrated genomics. Cold Spring Harb Symp Quant Biol. 2005;70:25-34. EXC1. [pmid: 16869735].
153 Gasparini G. Metronomic scheduling: the future of chemotherapy?. Lancet Oncol. Dec. 2001;2(12):733-740. EXC1. [pmid: 11902515].
154 Gasparini G, Longo R, Torino F, et al. Therapy of breast cancer with molecular targeting agents. Ann Oncol. May. Suppl 4. 2005;16:iv28-iv36. EXC1. [pmid: 15923426].
155 Gatenby RA, Gawlinski ET. Mathematical models of tumour invasion mediated by transformation-induced alteration of microenvironmental pH. Novartis Found Symp. 2001;240:85-96. discussion-9. EXC1. [pmid: 11727939].
156 Gaur A, Jewell DA, Liang Y, et al. Characterization of microRNA expression levels and their biological correlates in human cancer cell lines. Cancer Res. Mar. 15. 2007;67(6):2456-2468. EXC1. [pmid: 17363563].
157 Generali D, Fox SB, Brizzi MP, et al. Down-regulation of phosphatidylinositol 3’-kinase/AKT/molecular target of rapamycin metabolic pathway by primary letrozole-based therapy in human breast cancer. Clin Cancer Res. 2008:2673-2680. EXC1. [pmid: 18451231].
158 Gevaert O, Daemen A, De Moor B, et al. A taxonomy of epithelial human cancer and their metastases. BMC Med Genomics. 2009;2:69. EXC1. [pmid: 20017941].
159 Gevaert O, De Smet F, Timmerman D, et al. Predicting the prognosis of breast cancer by integrating clinical and microarray data with Bayesian networks. Bioinformatics. Jul. 15. 2006;22(14):e184-e190. EXC1. [pmid: 16873470].
160 Gil-Bazo I, Ponz-Sarvise M, Panizo-Santos A, et al. Id-1 expression and prognosis in cancer: do antibodies matter?. Clin Transl Oncol. Jan. 2010;12(1):69. EXC1. [pmid: 20080475].
161 Giles FJ, Albitar M. Plasma-based testing as a new paradigm for clinical testing in hematologic diseases. Expert Rev Molec Diagn. 2007;7(5):615-623. EXC1. [pmid: 17892367].
162 Gill C, Dowling C, O’Neill AJ, et al. Effects of cIAP-1, cIAP-2 and XIAP triple knockdown on prostate cancer cell susceptibility to apoptosis, cell survival and proliferation. Mol Cancer. 2009;8:39. EXC1. [pmid: 19549337].
163 Giordano SH, Duan Z, Kuo YF, et al. Impact of a scientific presentation on community treatment patterns for primary breast cancer. J Natl Cancer Inst. 2006:382-388. EXC1. [pmid: 16537830].
164 Glas AM, Floore A, Delahaye LJ, et al. Converting a breast cancer microarray signature into a high-throughput diagnostic test. BMC Genomics. 2006;7:278. EXC1. [pmid: 17074082].
165 Glasser L, Meloni-Ehrig A, Joseph P, et al. Benign chronic neutropenia with abnormalities involving 16q22, affecting mother and daughter. Am J Hematol. 2006;81(4):262-270. EXC1. [pmid: 16550514].
166 Goede V, Coutelle O, Neuneier J, et al. Identification of serum angiopoietin-2 as a biomarker for clinical outcome of colorectal cancer patients treated with bevacizumab-containing therapy. Br J Cancer. Oct. 26. 2010;103(9):1407-1414. EXC1. [pmid: 20924372].
167 Goozner M. From gene testing to the bedside: workshop focuses on future strategies. J Natl Cancer Inst. Aug. 3. 2011;103(15):1150-1151. EXC1. [pmid: 21768535].
168 Gopaldas R, Kunasani R, Plymyer MR, et al. Hepatoid malignancy of unknown origin--a diagnostic conundrum: review of literature and case report of collision with adenocarcinoma. Surg Oncol. Jul. 2005;14(1):11-25. EXC1, EXC3. [pmid: 15777886].
169 Gottesman MM. Mechanisms of cancer drug resistance. Annu Rev Med. 2002;53:615-627. EXC1. [pmid: 11818492].
170 Grann VR, Patel PR, Jacobson JS, et al. Comparative effectiveness of screening and prevention strategies among BRCA1/2-affected mutation carriers (Structured abstract). Breast Cancer Res Treat. 2011:837-847. EXC1. [pmid: 20644999].
171 Greco FA. Evolving Understanding and Current Management of Patients with Cancer of Unknown Primary Site. Commun Oncol. 2010;7:183-188. hand search, EXC2.
172 Greco FA, Erlander MG. Molecular classification of cancers of unknown primary site. Mol Diagn Ther. Dec. 1. 2009;13(6):367-373. hand search, EXC2. [pmid: 19925034]. Greco F Anthony, Erlander Mark G. Review New Zealand Molecular diagnosis &amp therapy. Mol Diagn Ther. Dec. 1. 2009;13(6):367-373. [doi: 10.2165/11530360-000000000-00000]. [pmid: 19925034].
173 Gudjonsson T, Villadsen R, Ronnov-Jessen L, et al. Immortalization protocols used in cell culture models of human breast morphogenesis. Cell Mol Life Sci. Oct. 2004;61(19–20):2523-2534. EXC1. [pmid: 15526159].
174 Gudmundsson J, Besenbacher S, Sulem P, et al. Genetic correction of PSA values using sequence variants associated with PSA levels. Sci Transl Med. Dec. 15. 2010;2(62):62ra92. EXC1. [pmid: 21160077].
175 Gunn SR, Mohammed MS, Gorre ME, et al. Whole-genome scanning by array comparative genomic hybridization as a clinical tool for risk assessment in chronic lymphocytic leukemia. J Mol Diagn. Sep. 2008;10(5):442-451. EXC1. [pmid: 18687794].
176 Gupta GP, Perk J, Acharyya S, et al. ID genes mediate tumor reinitiation during breast cancer lung metastasis. Proc Natl Acad Sci U S A. Dec. 4. 2007;104(49):19506-19511. EXC1. [pmid: 18048329].
177 Gupta S, Ashfaq R, Kapur P, et al. Microsatellite Instability May Be Uncommon Among Hispanics with Colorectal Cancer. Gastroenterology. May. 2009;136(5, Suppl. 1):A305. EXC1.
178 Gutierrez HR, Hornberger JC, Varadhachary GR, et al. Clinical utility of gene-expression profiling for tumor site origin. J Clin Oncol. 2011;29. suppl; abstr e21093. hand search EXC: updated by Nystrom article.
179 Guy M, Kote-Jarai Z, Giles GG, et al. Identification of new genetic risk factors for prostate cancer. Asian J Androl. Jan. 2009;11(1):49-55. EXC1. [pmid: 19050691].
180 Haferlach T, Kohlmann A, Bacher U, et al. Gene expression profiling for the diagnosis of acute leukaemia. Br J Cancer. Feb. 26. 2007;96(4):535-540. EXC1. [pmid: 17146476].
181 Hafner N, Diebolder H, Jansen L, et al. Hypermethylated DAPK in serum DNA of women with uterine leiomyoma is a biomarker not restricted to cancer. Gynecol Oncol. Apr. 2011;121(1):224-229. EXC1. [pmid: 21159370].
182 Hagenkord JM, Monzon FA, Kash SF, et al. Array-based karyotyping for prognostic assessment in chronic lymphocytic leukemia: performance comparison of Affymetrix 10K2.0, 250K Nsp and SNP6.0 arrays. J Mol Diagn. Mar. 2010;12(2):184-196. EXC1. [pmid: 20075210].
183 Hainsworth J, Henner D, Pillai R, et al. Molecular Tumor Profiling in the Diagnosis of Patients with Carcinoma of Unknown Primary (CUP) Retrospective Evaluation of the Tissue of Origin Test (Pathwork Diagnostics). ASCO-NCI-EORTC. 2010 October 18–20. Hollywood, FL. hand search.
184 Hainsworth JD, Spigel DR, Clark BL, et al. Paclitaxel/carboplatin/etoposide versus gemcitabine/irinotecan in the first-line treatment of patients with carcinoma of unknown primary site: a randomized, phase III Sarah Cannon Oncology Research Consortium Trial. Cancer J. 2010;(1):70-75. EXC1. [pmid: 20164695].
185 Haltrich I, Kost-Alimova M, Kovacs G, et al. Multipoint interphase FISH analysis of chromosome 3 abnormalities in 28 childhood AML patients. Eur J Haematol. Feb. 2006;76(2):124-133. EXC1. [pmid: 16405433].
186 Hayes, Inc. ProOnc TumorSourceDX miRview mets (Prometheus Laboratories; Rosetta Genomics) microRNA Analysis for Carcinoma of Unknown Primary Origin (CUP) (Structured abstract). Lansdale, PA. HAYES, Inc. 2009. EXC2 - ARTICLE NOT RETRIEVEABLE.
187 He QY, Zhou Y, Wong E, et al. Proteomic analysis of a preneoplastic phenotype in ovarian surface epithelial cells derived from prophylactic oophorectomies. Gynecol Oncol. Jul. 2005;98(1):68-76. EXC1. [pmid: 15913737].
188 Hede K. Small RNAs are raising big expectations. J Natl Cancer Inst. Jun. 16. 2009;101(12):840-841. EXC4. [pmid: 19509361].
189 Helmes AW, Bowen DJ, Bowden R, et al. Predictors of participation in genetic research in a primary care physician network. Cancer Epidemiol Biomarkers Prevent. 2000:1377-1379. EXC1.
190 Hemminki K, Ji J, Sundquist J, et al. Familial risks in cancer of unknown primary: tracking the primary sites. J Clin Oncol. Feb. 1. 2011;29(4):435-440. EXC1. [pmid: 21189391].
191 Henderson NC, Collis EA, Mackinnon AC, et al. CD98hc (SLC3A2) interaction with beta 1 integrins is required for transformation. J Biol Chem. Dec. 24. 2004;279(52):54731-54741. EXC1. [pmid: 15485886].
192 Henner WD. TechSectors - Diagnostics: Genomics-based tests can help diagnose uncertain cancers. Oncology Net Guide. 2008;9(7):32. hand search, EXC2.
193 Herborn CU, Unkel C, Vogt FM, et al. Whole-body MRI for staging patients with head and neck squamous cell carcinoma. Acta Otolaryngol (Stockh). 2005:1224-1229. EXC1. [pmid: 16353407].
194 Hewett R, Kijsanayothin P. Tumor classification ranking from microarray data. BMC Genomics. Suppl 2. 2008;9:S21. EXC1. [pmid: 18831787].
195 Higashikawa K, Yoneda S, Tobiume K, et al. DeltaNp63alpha-dependent expression of Id-3 distinctively suppresses the invasiveness of human squamous cell carcinoma. Int J Cancer. Jun. 15. 2009;124(12):2837-2844. EXC1. [pmid: 19267405].
196 Horlings HM, van Laar RK, Kerst JM, et al. Gene expression profiling to identify the histogenetic origin of metastatic adenocarcinomas of unknown primary. J Clin Oncol. Sep. 20. 2008;26(27):4435-4441. EXC4. [pmid: 18802156].
197 Effect of a gene expression-based Tissue of Origin Test on patient management for difficult-to-diagnose primary cancers. ASCO GI. 2011. San Francisco, CA. EXC3.
198 Hough CD, Sherman-Baust CA, Pizer ES, et al. Large-scale serial analysis of gene expression reveals genes differentially expressed in ovarian cancer. Cancer Res. Nov. 15. 2000;60(22):6281-6287. EXC1. [pmid: 11103784].
199 Howell A, Robertson JF, Abram P, et al. Comparison of fulvestrant versus tamoxifen for the treatment of advanced breast cancer in postmenopausal women previously untreated with endocrine therapy: a multinational, double-blind, randomized trial. J Clin Oncol. 2004:1605-1613. EXC1. [pmid: 15117982].
200 Hsu D, Hsu M. Poster Session III8:00 a.m-2:00 p.m. Epilepsia. 2007. 2007/10//;48(s6)248+. EXC1, EXC3.
201 Hsu FD, Nielsen TO, Alkushi A, et al. Tissue microarrays are an effective quality assurance tool for diagnostic immunohistochemistry. Mod Pathol. Dec. 2002;15(12):1374-1380. EXC1. [pmid: 12481020].
202 Huang H, Campbell SC, Nelius T, et al. Alpha1-antitrypsin inhibits angiogenesis and tumor growth. Int J Cancer. Dec. 20. 2004;112(6):1042-1048. EXC1. [pmid: 15316942].
203 Huang TH, Wu F, Loeb GB, et al. Up-regulation of miR-21 by HER2/neu signaling promotes cell invasion. J Biol Chem. Jul. 3. 2009;284(27):18515-18524. EXC1. [pmid: 19419954].
204 Huebner G, Morawietz L, Floore A, et al. Comparative analysis of microarray testing and immunohistochemistry in patients with carcinoma of unknown primary - CUP syndrome. EJC Supplements. Sep. 2007;5(4):90-91. EXC1.
205 Huysentruyt LC, Seyfried TN. Perspectives on the mesenchymal origin of metastatic cancer. Cancer Metastasis Rev. Dec. 2010;29(4):695-707. EXC1. [pmid: 20839033].
206 International Breast Cancer Study, G. Castiglione-Gertsch M, O’Neill A, et al. Adjuvant chemotherapy followed by goserelin versus either modality alone for premenopausal lymph node-negative breast cancer: a randomized trial. J Natl Cancer Inst. 2003:1833-1846. EXC1. [pmid: 14679153].
207 Irigaray P, Newby JA, Clapp R, et al. Lifestyle-related factors and environmental agents causing cancer: An overview. Biomed Pharmacother. Dec. 2007;61(10):640-658. EXC1. [pmid: 18055160].
208 Ismael G, de Azambuja E, Awada A. Molecular profiling of a tumor of unknown origin. N Engl J Med. Sep. 7. 2006;355(10):1071-1072. EXC4. [pmid: 16957161].
209 Itahana K, Campisi J, Dimri GP. Mechanisms of cellular senescence in human and mouse cells. Biogerontology. 2004;5(1):1-10. EXC1. [pmid: 15138376].
210 Jakubauskas A, Valceckiene V, Andrekute K, et al. Discovery of two novel EWSR1/ATF1 transcripts in four chimerical transcripts-expressing clear cell sarcoma and their quantitative evaluation. Exp Mol Pathol. 2011;90(2):194-200. EXC1. [pmid: 21185830].
211 Jang TJ, Jung KH, Choi EA. Id-1 gene downregulation by sulindac sulfide and its upregulation during tumor development in gastric cancer. Int J Cancer. Mar. 15. 2006;118(6):1356-1363. EXC1. [pmid: 16184548].
212 Jankowska A, Gunderson SI, Andrusiewicz M, et al. Reduction of human chorionic gonadotropin beta subunit expression by modified U1 snRNA caused apoptosis in cervical cancer cells. Mol Cancer. Mar. 14. 2008;7:26. EXC1. [pmid: 18339208].
213 Jessani N, Liu Y, Humphrey M, et al. Enzyme activity profiles of the secreted and membrane proteome that depict cancer cell invasiveness. Proc Natl Acad Sci U S A. Aug. 6. 2002;99(16):10335-10340. EXC1. [pmid: 12149457].
214 Jilani I, Keating M, Day A, et al. Simplified sensitive method for the detection of B-cell clonality in lymphoid malignancies. Clin Lab Haematol. Oct. 2006;28(5):325-331. EXC1. [pmid: 16999724].
215 Jilani I, Wei C, Bekele BN, et al. Soluble syndecan-1 (sCD138) as a prognostic factor independent of mutation status in patients with chronic lymphocytic leukemia. Int J Lab Hematol. Feb. 2009;31(1):97-105. EXC1. [pmid: 18190591].
216 Joergensen MT, Brusgaard K, Cruger DG, et al. Genetic, epidemiological, and clinical aspects of hereditary pancreatitis: a population-based cohort study in Denmark. Am J Gastroenterol. Aug. 2010;105(8):1876-1883. EXC1. [pmid: 20502448].
217 Judson I, Radford JA, Harris M, et al. Randomised phase II trial of pegylated liposomal doxorubicin (DOXIL/CAELYX) versus doxorubicin in the treatment of advanced or metastatic soft tissue sarcoma: a study by the EORTC Soft Tissue and Bone Sarcoma Group. Eur J Cancer. 2001:870-877. EXC1. [pmid: 11313175].
218 Juric D, Sale S, Hromas RA, et al. Gene expression profiling differentiates germ cell tumors from other cancers and defines subtype-specific signatures. Proc Natl Acad Sci U S A. Dec. 6. 2005;102(49):17763-17768. EXC1. [pmid: 16306258].
219 Kalof AN, Evans MF, Cooper K. 1 - Special Diagnostic techniques in surgical pathology. Diff Diagn Surg Pathol. 2010:1-38. EXC1.
220 Karahatay S, Thomas K, Koybasi S, et al. Clinical relevance of ceramide metabolism in the pathogenesis of human head and neck squamous cell carcinoma (HNSCC): attenuation of C(18)-ceramide in HNSCC tumors correlates with lymphovascular invasion and nodal metastasis. Cancer Lett. 2007:101-111. EXC1. [pmid: 17619081].
221 Karanikas V, Speletas M, Zamanakou M, et al. Foxp3 expression in human cancer cells. J Transl Med. 2008;6:19. EXC1. [pmid: 18430198].
222 Kato N, Honma K, Hojo H, et al. KIT expression in normal and neoplastic renal tissues: immunohistochemical and molecular genetic analysis. Pathol Int. Aug. 2005;55(8):479-483. EXC1. [pmid: 15998375].
223 Kato N, Motoyama T, Kameda N, et al. Primary carcinoid tumor of the testis: Immunohistochemical, ultrastructural and FISH analysis with review of the literature. Pathol Int. Oct. 2003;53(10):680-685. EXC1. [pmid: 14516318].
224 Kato N, Tsuchiya T, Tamura G, et al. E-cadherin expression in follicular carcinoma of the thyroid. Pathol Int. Jan. 2002;52(1):13-18. EXC1. [pmid: 11940201].
225 Katz E, Dubois-Marshall S, Sims AH, et al. A gene on the HER2 amplicon, C35, is an oncogene in breast cancer whose actions are prevented by inhibition of Syk. Br J Cancer. Jul. 27. 2010;103(3):401-410. EXC1. [pmid: 20628393].
226 Kawata S, Yamasaki E, Nagase T, et al. Effect of pravastatin on survival in patients with advanced hepatocellular carcinoma. A randomized controlled trial. Br J Cancer. 2001:886-891. EXC1. [pmid: 11286466].
227 Kebebew E, Treseler PA, Duh QY, et al. The helix-loop-helix protein, Id-1, is overexpressed and regulates growth in papillary thyroid cancer. Surgery. Aug. 2003;134(2):235-241. EXC1. [pmid: 12947323].
228 Keeling P. Role of the opportunity to test index in integrating diagnostics with therapeutics. Personalized Medicine. 2006;3(4):399-407. EXC1.
229 Kennedy RD, Quinn JE, Johnston PG, et al. BRCA1: Mechanisms of inactivation and implications for management of patients. Lancet (North American Edition). September. 28. 2002;360(9338):1007-1014. EXC1.
230 Khoury JD. Ewing sarcoma family of tumors: a model for the new era of integrated laboratory diagnostics. Expert Rev Mol Diagn. Jan. 2008;8(1):97-105. EXC2 -BACKGROUND at FT Stage. [pmid: 18088234].
231 Kikuchi N, Ogino T, Kashiwa H, et al. Trichorhinophalangeal syndrome type II without the chromosome 8 deletion that resembled metachondromatosis. Congenit Anom (Kyoto). Sep. 2007;47(3):105-107. EXC1. [pmid: 17688470].
232 Kim JH, Jeoung D, Lee S, et al. Discovering significant and interpretable patterns from multifactorial DNA microarray data with poor replication. J Biomed Inform. Aug. 2004;37(4):260-268. EXC1. [pmid: 15465479].
233 Kim TJ, Choi JJ, Kim WY, et al. Gene expression profiling for the prediction of lymph node metastasis in patients with cervical cancer. Cancer Sci. Jan. 2008;99(1):31-38. EXC1. [pmid: 17986283].
234 King BL, Crisi GM, Tsai SC, et al. Immunocytochemical analysis of breast cells obtained by ductal lavage. Cancer. Aug. 25. 2002;96(4):244-249. EXC1. [pmid: 12209667].
235 Klein P, Prolla G, Wallach R, et al. BRCA1 germline mutation presenting as an adenocarcinoma of unknown primary. Cancer J. May-Jun. 2000;6(3):188-190. EXC1. [pmid: 10882335].
236 Koessler T, Oestergaard MZ, Song H, et al. Common variants in mismatch repair genes and risk of colorectal cancer. Gut. Aug. 2008;57(8):1097-1101. EXC1. [pmid: 18364438].
237 Koga H, Sasaki M, Kuwabara Y, et al. Lesion detectability of a gamma camera based coincidence system with FDG in patients with malignant tumors: a comparison with dedicated positron emission tomography. Ann Nucl Med. 2004:131-136. EXC1. [pmid: 15195760].
238 Kohno N, Aogi K, Minami H, et al. A randomized, double-blind, placebo-controlled phase III trial of zoledonic acid in the prevention of skeletal complications in Japanese women with bone metastases from breast cancer [abstract]. Annual Meeting Proceedings of the American Society of Clinical Oncology. 2004:43. EXC1.
239 Koopman LA, Corver WE, van der Slik AR, et al. Multiple genetic alterations cause frequent and heterogeneous human histocompatibility leukocyte antigen class I loss in cervical cancer. J Exp Med. March. 20. 2000;191(6):961-975. EXC1. [pmid: 10727458].
240 Korenberg MJ, Farinha P, Gascoyne RD. Predicting survival in follicular lymphoma using tissue microarrays. Methods Mol Biol. 2007;377:255-268. EXC1. [pmid: 17634622].
241 Kovar H. Context matters: the hen or egg problem in Ewing’s sarcoma. Semin Cancer Biol. Jun. 2005;15(3):189-196. EXC1. [pmid: 15826833].
242 Koyanagi K, Mori T, O’Day SJ, et al. Association of circulating tumor cells with serum tumor-related methylated DNA in peripheral blood of melanoma patients. Cancer Res. Jun. 15. 2006;66(12):6111-6117. XC1. [pmid: 16778184].
243 Kozak KR, Crews BC, Ray JL, et al. Metabolism of prostaglandin glycerol esters and prostaglandin ethanolamides in vitro and in vivo. J Biol Chem. Oct. 5. 2001;276(40):36993-36998. EXC1. [pmid: 11447235].
244 Kumaraswamy S, Chinnaiyan P, Shankavaram UT, et al. Radiation-induced gene translation profiles reveal tumor type and cancer-specific components. Cancer Res. May. 15. 2008;68(10):3819-3826. BKG, EXC2. [pmid: 18483266].
245 Kurdistani SK. Histone modifications in cancer biology and prognosis. Prog Drug Res. 2011;67:91-106. Exc1. [pmid: 21141726].
246 Ladanyi M, Bridge JA. Contribution of molecular genetic data to the classification of sarcomas. Hum Pathol. May. 2000;31(5):532-538. hand search, EXC2. [pmid: 10836292].
247 Lal A, Panos A, Marjanovic M, et al. A Gene Expression Profile Test for the Differential Diagnosis of Ovarian Versus Endometrial Cancers. Cancer Cytogenomics Microarray Consortium Summer Meeting. 2011 August 8. Chicago, IL. hand search, EXC1.
248 Lamb JD, Garcia RL, Goff BA, et al. Predictors of occult neoplasia in women undergoing risk-reducing salpingo-oophorectomy. Am J Obstet Gynecol. Jun. 2006;194(6):1702-1709. EXC1. [pmid: 16731090].
249 Landolsi H, Missaoui N, Yacoubi MT, et al. Assessment of the role of histopathology and DNA image analysis in the diagnosis of molar and non-molar abortion: a study of 89 cases in the center of Tunisia. Pathol Res Pract. 2009;205(11):789-796. EXC1. [pmid: 19665315].
250 Last K, Debarnardi S, Lister TA. Molecular diagnosis of lymphoma: outcome prediction by gene expression profiling in diffuse large B-cell lymphoma. Methods Mol Med. 2005;115:15-63. EXC1. [pmid: 15998962].
251 Latief KH, White CS, Protopapas Z, et al. Search for a primary lung neoplasm in patients with brain metastasis: is the chest radiograph sufficient?. Am J Roentgenol. May. 1997;168(5):1339-1344. BKG, EXC1. [pmid: 9129439].
252 Le Cesne A, Ray-Coquard I, Bui BN, et al. Discontinuation of imatinib in patients with advanced gastrointestinal stromal tumours after 3 years of treatment: an open-label multicentre randomised phase 3 trial. Lancet Oncol. 2010:942-949. EXC1. [pmid: 20864406].
253 Lebrec D, Thabut D, Oberti F, et al. Pentoxifylline does not decrease short-term mortality but does reduce complications in patients with advanced cirrhosis. Gastroenterology. 2010:1755-1762. EXC1. [pmid: 20102716].
254 Lee CH, Subramanian S, Beck AH, et al. MicroRNA profiling of BRCA1/2 mutation-carrying and non-mutation-carrying high-grade serous carcinomas of ovary. PLoS One. 2009;4(10):e7314. EXC1. [pmid: 19798417].
255 Lee DW, Bueso-Ramos CE, Carroll M, et al. SHIP1 Is a Novel Tumor Suppressor in Late-Stage Myelodysplastic Syndromes and Is Silenced by Mir-210 and Mir-155. Blood. Nov. 20. 2009;114(22):1471. EXC1.
256 Lee FT, O’Keefe GJ, Gan HK, et al. Immuno-PET quantitation of de2-7 epidermal growth factor receptor expression in glioma using 124I-IMP-R4-labeled antibody ch806. J Nucl Med. Jun. 2010;51(6):967-972. EXC1. [pmid: 20484439].
257 Lee J, Hopcus-Niccum DJ, Mulvihill JJ, et al. Cytogenetic and molecular cytogenetic studies of a variant of t(21;22), ins(22;21)(q12;q21q22), with a deletion of the 3’ EWSR1 gene in a patient with Ewing sarcoma. Cancer Genet Cytogenet. Jun. 2005;159(2):177-180. hand search, EXC2. [pmid: 15899394].
258 Lee KT, Lee YW, Lee JK, et al. Overexpression of Id-1 is significantly associated with tumour angiogenesis in human pancreas cancers. Br J Cancer. Mar. 22. 2004;90(6):1198-1203. EXC1. [pmid: 15026801].
259 Lee Y, Lee CK. Classification of multiple cancer types by multicategory support vector machines using gene expression data. Bioinformatics. Jun. 12. 2003;19(9):1132-1139. EXC1. [pmid: 12801874].
260 Leong SP, Nakakura EK, Pollock R, et al. Unique patterns of metastases in common and rare types of malignancy. J Surg Oncol. May. 1. 2011;103(6):607-614. hand search, EXC2. [pmid: 21480255].
261 Lequin D, Fizazi K, Toujani S, et al. Biological characterization of two xenografts derived from human CUPs (carcinomas of unknown primary). BMC Cancer. 2007;7:225. EXC1. [pmid: 18088404].
262 Lewison G, Grant J, Jansen P. International gastroenterology research: subject areas, impact, and funding. Gut. 2001:295-302. EXC2. [pmid: 11454809].
263 Li H, Luan Y. Boosting proportional hazards models using smoothing splines, with applications to high-dimensional microarray data. Bioinformatics. May. 15. 2005;21(10):2403-2409. EXC1. [pmid: 15713732].
264 Li J, Jia H, Xie L, et al. Correlation of inhibitor of differentiation 1 expression to tumor progression, poor differentiation and aggressive behaviors in cervical carcinoma. Gynecol Oncol. Jul. 2009;114(1):89-93. EXC1. [pmid: 19359031].
265 Li W, Fan M, Xiong M. SamCluster: an integrated scheme for automatic discovery of sample classes using gene expression profile. Bioinformatics. May. 1. 2003;19(7):811-817. EXC1. [pmid: 12724290].
266 Li X, Liu W, Cheung K-F, et al. Epigenetic Characterization of RAS Association Domain-Containing Protein 10 as a Functional Tumor Suppressor in Gastric Cancer. Gastroenterology. May. 2011;140(5, Suppl. 1):S144-S145. EXC1.
267 Li ZB, Chen YX, Zhao JY, et al. Effects of pharmacological concentrations of estrogens on growth of 3AO human ovarian cancer cells. Yi Chuan Xue Bao. Sep. 2006;33(9):782-792. EXC1. [pmid: 16980124].
268 Lin CQ, Singh J, Murata K, et al. A role for Id-1 in the aggressive phenotype and steroid hormone response of human breast cancer cells. Cancer Res. Mar. 1. 2000;60(5):1332-1340. EXC1. [pmid: 10728695].
269 Ling MT, Kwok WK, Fung MK, et al. Proteasome mediated degradation of Id-1 is associated with TNFalpha-induced apoptosis in prostate cancer cells. Carcinogenesis. Feb. 2006;27(2):205-215. EXC1. [pmid: 16123120].
270 Linton K, Hey Y, Dibben S, et al. Methods comparison for high-resolution transcriptional analysis of archival material on Affymetrix Plus 2.0 and Exon 1.0 microarrays. Biotechniques. Jul. 2009;47(1):587-596. EXC1. [pmid: 19594443].
271 Liu JJ, Cutler G, Li W, et al. Multiclass cancer classification and biomarker discovery using GA-based algorithms. Bioinformatics. Jun. 1. 2005;21(11):2691-2697. EXC1. [pmid: 15814557].
272 Liu S, Kim YS, Zhai S, et al. Evaluation of (64)Cu(DO3A-xy-TPEP) as a potential PET radiotracer for monitoring tumor multidrug resistance. Bioconjug Chem. Apr. 2009;20(4):790-798. EXC1. [pmid: 19284752].
273 Lobins R, Floyd J. Small cell carcinoma of unknown primary. Semin Oncol. Feb. 2007;34(1):39-42. BKG, EXC2. [pmid: 17270664].
274 Loh Y, Duckwiler GR. Onyx Trial I. A prospective, multicenter, randomized trial of the Onyx liquid embolic system and N-butyl cyanoacrylate embolization of cerebral arteriovenous malformations. Clinical article. J Neurosurg. 2010:733-741. EXC1. [pmid: 20433277].
275 Lu YJ, Williamson D, Wang R, et al. Expression profiling targeting chromosomes for tumor classification and prediction of clinical behavior. Genes Chromosom Cancer. Nov. 2003;38(3):207-214. EXC1. [pmid: 14506694].
276 Luther SA, Lopez T, Bai W, et al. BLC expression in pancreatic islets causes B cell recruitment and lymphotoxin-dependent lymphoid neogenesis. Immunity. May. 2000;12(5):471-481. EXC1. [pmid: 10843380].
277 Ma W, Kantarjian H, Zhang X, et al. Detection of nucleophosmin gene mutations in plasma from patients with acute myeloid leukemia: Clinical significance and implications. Cancer Biomarkers. 2009;5(1):51-58. EMBASE tests, EXC1. [pmid: 19242062].
278 Ma W, Kantarjian H, Zhang X, et al. Ubiquitin-proteasome system profiling in acute leukemias and its clinical relevance. Leuk Res. 2011;35(4):526-533. EXC1. [pmid: 20951430].
279 Manthey C, Mern DS, Gutmann A, et al. Elevated endogenous expression of the dominant negative basic helix-loop-helix protein ID1 correlates with significant centrosome abnormalities in human tumor cells. BMC Cell Biol. 2010;11:2. EXC1. [pmid: 20070914].
280 Marcio M, Wendy L, Lindsay F, et al. Brain metastases in children with high risk germ cell tumors (GCT). A report from the Children’s Oncology Group (COG). Pediatr Blood Cancer. 2008:108. EXC1.
281 Marfori JE, Exner MM, Marousek GI, et al. Development of new cytomegalovirus UL97 and DNA polymerase mutations conferring drug resistance after valganciclovir therapy in allogeneic stem cell recipients. J Clin Virol. 2007;38(2):120-125. EXC1. [pmid: 17157554].
282 Mark HF, Bai H, Sotomayor E, et al. Hypotetraploidy in a patient with small cell carcinoma. Exp Mol Pathol. Feb. 2000;68(1):70-76. EXC1. [pmid: 10640456].
283 Marti GE, Shim YK, Albitar M, et al. Long-term follow-up of monoclonal B-cell lymphocytosis detected in environmental health studies. Cytometry Part B - Clinical Cytometry. SUPPL. 1. 2010;78:S83-S90. EXC1.
284 Masiá M, Bernal E, Padilla S, et al. A pilot randomized trial comparing an intensive versus a standard intervention in stable HIV-infected patients with moderate-high cardiovascular risk. J Antimicrob Chemother. 2009:589-598. EXC1. [pmid: 19625372].
285 Massard C, Voigt JJ, Laplanche A, et al. Carcinoma of an unknown primary: are EGF receptor, Her-2/neu, and c-Kit tyrosine kinases potential targets for therapy?. Br J Cancer. 2007:857-861. EXC1. [pmid: 17876336].
286 Maury S, Huguet F, Leguay T, et al. Adverse prognostic significance of CD20 expression in adults with Philadelphia chromosome-negative B-cell precursor acute lymphoblastic leukemia. Haematologica. Feb. 2010;95(2):324-328. EXC1. [pmid: 19773266].
287 McAllister SD, Christian RT, Horowitz MP, et al. Cannabidiol as a novel inhibitor of Id-1 gene expression in aggressive breast cancer cells. Mol Cancer Ther. Nov. 2007;6(11):2921-2927. EXC1. [pmid: 18025276].
288 McCormick BK, Erlander MG. Psychosocial Aspects of Treating Patients with Cancer of Unknown Primary (CUP): A Survey of Oncology Social Workers. Association of Oncology Social Work Annual Conference. 2009 May. hand search, EXC1.
289 McLarty K, Fasih A, Scollard DA, et al. 18F-FDG small-animal PET/CT differentiates trastuzumab-responsive from unresponsive human breast cancer xenografts in athymic mice. J Nucl Med. Nov. 2009;50(11):1848-1856. EXC1. [pmid: 19837760].
290 Medeiros F, Halling KC, Kolbert CP, et al. Ovarian mucinous neoplasms: Can gene expression microarray-based technology distinguish primary versus metastatic tumors?. International Congress of the International Academy of Pathology. 2008 October 12–17. Athens, Greece. hand search, EXC1.
291 Medina PP, Carretero J, Fraga MF, et al. Genetic and epigenetic screening for gene alterations of the chromatin-remodeling factor, SMARCA4/BRGI, in lung tumors. Genes Chromosom Cancer. October. 2004;41(2):170-177. EXC1. [pmid: 15287030].
292 Medina RA, Owen GI. Glucose transporters: expression, regulation and cancer. Biol Res. 2002;35(1):9-26. EXC1. [pmid: 12125211].
293 Meloni-Ehrig AM, Tirado CA, Chen K, et al. Isolated del(14)(q21) in a case of precursor B-cell acute lymphoblastic leukemia. Cancer Genet Cytogenet. 2005;161(1):82-85. EXC1. [pmid: 16080963].
294 Mern DS, Hasskarl J, Burwinkel B. Inhibition of Id proteins by a peptide aptamer induces cell-cycle arrest and apoptosis in ovarian cancer cells. Br J Cancer. Oct. 12. 2010;103(8):1237-1244. EXC1. [pmid: 20842131].
295 Miller AA, Wang XF, Bogart JA, et al. Phase II trial of paclitaxel-topotecan-etoposide followed by consolidation chemoradiotherapy for limited-stage small cell lung cancer: CALGB 30002. J Thorac Oncol. 2007:645-651. EXC1. [pmid: 17607121].
296 Mischel PS, Cloughesy TF, Nelson SF. DNA-microarray analysis of brain cancer: molecular classification for therapy. Nat Rev Neurosci. Oct. 2004;5(10):782-792. BKG, EXC2. [pmid: 15378038].
297 Monzon FA, Dumur CI. Diagnosis of uncertain primary tumors with the Pathwork tissue-of-origin test. Expert Rev Mol Diagn. Jan. 2010;10(1):17-25. EXC4. [pmid: 20014919].
298 Monzon FA, Koen TJ. Diagnosis of Metastatic Neoplasms Molecular Approaches for Identification of Tissue of Origin. Arch Pathol Lab Med. Feb. 2010;134(2):216-224. EXC4. [pmid: 20121609].
299 Morawietz L, Floore A, Stork-Sloots L, et al. Comparison of histopathological and gene expression-based typing of cancer of unknown primary. Virchows Arch. Jan. 2010;456(1):23-29. EXC4. [pmid: 20012089].
300 Motakis E, Ivshina AV, Kuznetsov VA. Data-driven approach to predict survival of cancer patients: estimation of microarray genes’ prediction significance by Cox proportional hazard regression model. IEEE Eng Med Biol Mag. Jul-Aug. 2009;28(4):58-66. EXC1. [pmid: 19622426].
301 Mouridsen H, Gershanovich M, Sun Y, et al. Superior efficacy of letrozole versus tamoxifen as first-line therapy for postmenopausal women with advanced breast cancer: results of a phase III study of the International Letrozole Breast Cancer Group. J Clin Oncol. 2001:2596-2606. EXC1. [pmid: 11352951].
302 Mungall AJ, Morin RD, An J, et al. Recurrent DNA Mutations In Non-Hodgkin Lymphomas Reveal Candidate Therapeutic Targets. Blood. Nov. 19. 2010;116(21):277-278. EXC1.
303 Nabholtz JM, Buzdar A, Pollak M, et al. Anastrozole is superior to tamoxifen as first-line therapy for advanced breast cancer in postmenopausal women: Results of a North American multicenter randomized trial. J Clin Oncol. 2000:3758-3767. EXC1. [pmid: 11078488].
304 Nanda D, de Jong M, Vogels R, et al. Imaging expression of adenoviral HSV1-tk suicide gene transfer using the nucleoside analogue FIRU. Eur J Nucl Med Mol Imaging. Jul. 2002;29(7):939-947. EXC1. [pmid: 12212546].
305 Nanni C, Rubello D, Castellucci P, et al. Role of 18F-FDG PET-CT imaging for the detection of an unknown primary tumor: preliminary results in 21 patients. Eur J Nucl Med Mol Imaging. 2005;32:589-592. EXC1. [pmid: 15726356].
306 Naora H. Developmental patterning in the wrong context: the paradox of epithelial ovarian cancers. Cell Cycle. Aug. 2005;4(8):1033-1035. EXC1. [pmid: 16082202].
307 Nasedkina T, Domer P, Zharinov V, et al. Identification of chromosomal translocations in leukemias by hybridization with oligonucleotide microarrays. Haematologica. Apr. 2002;87(4):363-372. BKG, EXC1. [pmid: 11940480].
308 Natoli C, Ramazzotti V, Nappi O, et al. Unknown primary tumors. Biochim Biophys Acta. Aug. 2011;1816(1):13-24. BKG at Title and Abstract Review, EXC2. [pmid: 21371531].
309 Natoli C, Ramazzotti V, Nappi O, et al. Unknown primary tumors. 2011. http://www.sciencedirect.com/science?_ob=GatewayURL&_origin=ScienceSearch&_method=citationSearch&_piikey=S0304419X11000059&_version=1&_returnURL=http%3A%2F%2Fwww.scirus.com%2Fsrsapp%2F&md5=c68facd82949289a726ca39624dc9fa91816. EXC2 SCIRUS.
310 Nawrocki S, Krzakowski M, Wasilewska-Tesluk E, et al. Concurrent chemotherapy and short course radiotherapy in patients with stage IIIA to IIIB non-small cell lung cancer not eligible for radical treatment: results of a randomized phase II study. J Thorac Oncol. 2010:1255-1262. EXC1. [pmid: 20592630].
311 Naxerova K, Bult CJ, Peaston A, et al. Analysis of gene expression in a developmental context emphasizes distinct biological leitmotifs in human cancers. Genome Biol. 2008;9(7):R108. EXC1. [pmid: 18611264].
312 Nelson HD, Huffman LH, Fu R, et al. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: Systematic evidence review for the US Preventive Services Task Force. Ann Intern Med. Sep. 6. 2005;143(5):362-379. EXC1. [pmid: 16144895].
313 Neuman M, Angulo P, Malkiewicz I, et al. Tumor necrosis factor-alpha and transforming growth factor-beta reflect severity of liver damage in primary biliary cirrhosis. J Gastroenterol Hepatol. 2002:196-202. EXC1. [pmid: 11966951].
314 Nilsson B, Andersson A, Johansson M, et al. Cross-platform classification in microarray-based leukemia diagnostics. Haematologica. Jun. 2006;91(6):821-824. EXC1. [pmid: 16769585].
315 Nuyten DS, van de Vijver MJ. Using microarray analysis as a prognostic and predictive tool in oncology: focus on breast cancer and normal tissue toxicity. Semin Radiat Oncol. Apr. 2008;18(2):105-114. BKG, EXC2. [pmid: 18314065].
316 O’Brien CS, Howell SJ, Farnie G, et al. Resistance to endocrine therapy: are breast cancer stem cells the culprits?. J Mammary Gland Biol Neoplasia. Mar. 2009;14(1):45-54. EXC1. [pmid: 19252972].
317 Oguz A, Karadeniz C, Citak EC, et al. Experience with cefepime versus meropenem as empiric monotherapy for neutropenia and fever in pediatric patients with solid tumors. Pediatr Hematol Oncol. 2006:245-253. EXC1. [pmid: 16517540].
318 Ohira M, Oba S, Nakamura Y, et al. Expression profiling using a tumor-specific cDNA microarray predicts the prognosis of intermediate risk neuroblastomas. Cancer Cell. Apr. 2005;7(4):337-350. BKG, EXC1. [pmid: 15837623].
319 Ohta N, Suzuki H, Fukase S, et al. Primary non-Hodgkin’s lymphoma of the larynx (Stage IE) diagnosed by gene rearrangement. J Laryngol Otol. Jul. 2001;115(7):596-599. EXC1. [pmid: 11485601].
320 Oien KA, Evans TR. Raising the profile of cancer of unknown primary. J Clin Oncol. Sep. 20. 2008;26(27):4373-4375. EXC4. [pmid: 18802148].
321 Oksjoki S, Soderstrom M, Inki P, et al. Molecular profiling of polycystic ovaries for markers of cell invasion and matrix turnover. Fertil Steril. Apr. 2005;83(4):937-944. EXC1. [pmid: 15820804].
322 Olsen SJ, Malvern KT, May BJ, et al. Partnership with an African American sorority to enhance participation in cancer genetics research. Community Genet. 2008:201-207. EXC1. [pmid: 18417967].
323 Orui H, Yamakawa M, Ishikawa A, et al. Malignant intramuscular forearm tumor with overwhelming squamous element. Pathol Int. Jul. 2000;50(7):574-578. EXC1. [pmid: 10886743].
324 Ovchinnikov DA. Macrophages in the embryo and beyond: much more than just giant phagocytes. Genesis. Sep. 2008;46(9):447-462. EXC1. [pmid: 18781633].
325 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-523. EXC1. [pmid: 19595577].
326 Ozdag H, Teschendorff AE, Ahmed AA, et al. Differential expression of selected histone modifier genes in human solid cancers. BMC Genomics. 2006;7:90. EXC1. [pmid: 16638127].
327 Paganini H, Rodriguez-Brieshcke T, Zubizarreta P, et al. Oral ciprofloxacin in the management of children with cancer with lower risk febrile neutropenia: A randomized controlled trial. Cancer. 2001:1563-1567. EXC1. [pmid: 11301406].
328 Pandya KJ, Hu P, Osborne CK, et al. Phase III study of standard combination versus rotating regimen of induction chemotherapy in patients with hormone insensitive metastatic breast cancer: an Eastern Cooperative Oncology Group Intergroup Study (E3185). Am J Clin Oncol. 2007:113-125. EXC1. [pmid: 17414459].
329 Park SH, Gray WC, Hernandez I, et al. Phase I trial of all-trans retinoic acid in patients with treated head and neck squamous carcinoma. Clin Cancer Res. 2000:847-854. EXC1. [pmid: 10741706].
330 Pasqualini R, Moeller BJ, Arap W. Leveraging molecular heterogeneity of the vascular endothelium for targeted drug delivery and imaging. Semin Thromb Hemost. Apr. 2010;36(3):343-351. EXC1. [pmid: 20490984].
331 Pataraia E. Abstracts of the 5th Joint Meeting of the German, Austrian, and Swiss Sections of the International League Against Epilepsy Basle, May 16-19, 2007. Epilepsia. 2007. 2007/06//;48(s3)1+. EXC1.
332 Patel A, Kang SH, Lennon PA, et al. Validation of a targeted DNA microarray for the clinical evaluation of recurrent abnormalities in chronic lymphocytic leukemia. Am J Hematol. Jul. 2008;83(7):540-546. EXC1. [pmid: 18161787].
333 Paudyal P, Paudyal B, Hanaoka H, et al. Imaging and biodistribution of Her2/neu expression in non-small cell lung cancer xenografts with Cu-labeled trastuzumab PET. Cancer Sci. Apr. 2010;101(4):1045-1050. EXC1. [pmid: 20219072].
334 Pavicic W, Perkio E, Kaur S, et al. Altered methylation at microRNA-associated CpG islands in hereditary and sporadic carcinomas: a methylation-specific multiplex ligation-dependent probe amplification (MS-MLPA)-based approach. Mol Med. 2011;17(7–8):726-735. EXC1. [pmid: 21327300].
335 Pavlidis N, Pentheroudakis G, Plataniotis G. Cervical lymph node metastases of squamous cell carcinoma from an unknown primary site: a favourable prognosis subset of patients with CUP. Clin Transl Oncol. Jun. 2009;11(6):340-348. EXC2. [pmid: 19531448].
336 Penland SK, Keku TO, Torrice C, et al. RNA expression analysis of formalin-fixed paraffin-embedded tumors. Lab Invest. Apr. 2007;87(4):383-391. EXC1. [pmid: 17297435].
337 Pentheroudakis G, Briasoulis E, Pavlidis N. Cancer of unknown primary site: missing primary or missing biology?. Oncologist. Apr. 2007;12(4):418-425. EXC4. [pmid: 17470684].
338 Pentheroudakis G, Golfinopoulos V, Pavlidis N. Switching benchmarks in cancer of unknown primary: from autopsy to microarray. Eur J Cancer. Sep. 2007;43(14):2026-2036. BKG at Title and Abstract Stage EXC4. [pmid: 17698346].
339 Petalidis LP, Oulas A, Backlund M, et al. Improved grading and survival prediction of human astrocytic brain tumors by artificial neural network analysis of gene expression microarray data. Mol Cancer Ther. May. 2008;7(5):1013-1024. EXC1. [pmid: 18445660].
340 Petersen I, Hidalgo A, Petersen S, et al. Chromosomal imbalances in brain metastases of solid tumors. Brain Pathol. Jul. 2000;10(3):395-401. INC at Title and Abstract Stage. [pmid: 10885658].
341 Petrilli AS, Dantas LS, Campos MC, et al. Oral ciprofloxacin vs. intravenous ceftriaxone administered in an outpatient setting for fever and neutropenia in low-risk pediatric oncology patients: randomized prospective trial. Med Pediatr Oncol. 2000:87-91. EXC1. [pmid: 10657866].
342 Petrowsky H, Breitenstein S, Slankamenac K, et al. Effects of pentoxifylline on liver regeneration: a double-blinded, randomized, controlled trial in 101 patients undergoing major liver resection. Ann Surg. 2010:813-822. EXC1. [pmid: 21037437].
343 Pettus JA, Cowley BC, Maxwell T, et al. Multiple abnormalities detected by dye reversal genomic microarrays in prostate cancer: a much greater sensitivity than conventional cytogenetics. Cancer Genet Cytogenet. Oct. 15. 2004;154(2):110-118. EXC1. [pmid: 15474145].
344 Piek JM, Dorsman JC, Massuger LF, et al. BRCA1 and p53 protein expression in cultured ovarian surface epithelial cells derived from women with and without a BRCA1 germline mutation. Arch Gynecol Obstet. Oct. 2006;274(6):327-331. EXC1. [pmid: 16826413].
345 Pillai R, Deeter R, Buturovic L, et al. Microarray-Based Gene Expression Assay for Identification of Primary Site Using Formalin-Fixed Paraffin-Embedded (FFPE) Tissue. ASCO, GI. 2010 January 22–24. Orlando, FL. hand search EXC3.
346 Pillai R, Deeter R, Rigl CT, et al. A Microarray-Based Gene Expression Test as an Aid to Tumor Diagnosis Using Formalin-Fixed Paraffin-Embedded (FFPE) Specimens. CAP. 2009 October 11-14. Washington, DC. hand search EXC3.
347 Pinguet F, Culine S, Bressolle F, et al. A phase I and pharmacokinetic study of melphalan using a 24-hour continuous infusion in patients with advanced malignancies. Clin Cancer Res. 2000:57-63. EXC1. [pmid: 10656432].
348 Pollack A. Genetic Tests May Reveal Source of Mystery Tumors. New York Times. 2009. EXC2.
349 Pon YL, Auersperg N, Wong AS. Gonadotropins regulate N-cadherin-mediated human ovarian surface epithelial cell survival at both post-translational and transcriptional levels through a cyclic AMP/protein kinase A pathway. J Biol Chem. Apr. 15. 2005;280(15):15438-15448. EXC1. [pmid: 15701645].
350 Post DE, Devi NS, Li Z, et al. Cancer therapy with a replicating oncolytic adenovirus targeting the hypoxic microenvironment of tumors. Clin Cancer Res. Dec. 15. 2004;10(24):8603-8612. EXC1. [pmid: 15623644].
351 Powell CB. Occult ovarian cancer at the time of risk-reducing salpingo-oophorectomy. Gynecol Oncol. Jan. 2006;100(1):1-2. EXC1. [pmid: 16368438].
352 Poznansky MC, Olszak IT, Foxall RB, et al. Tissue source dictates lineage outcome of human fetal CD34(+)CD38(−) cells. Exp Hematol. Jun. 2001;29(6):766-774. BKG, EXC1. [pmid: 11378272].
353 Ptitsyn AA, Weil MM, Thamm DH. Systems biology approach to identification of biomarkers for metastatic progression in cancer. BMC Bioinformatics. Suppl 9. 2008;9:S8. EXC1. [pmid: 18793472].
354 Qin ZX, Li QW, Liu GY, et al. Imaging targeted at tumor with (188)Re-labeled VEGF(189) exon 6-encoded peptide and effects of the transfecting truncated KDR gene in tumor-bearing nude mice. Nucl Med Biol. Jul. 2009;36(5):535-543. EXC1. [pmid: 19520294].
355 Qiu P, Wang ZJ, Liu KJ. Ensemble dependence model for classification and prediction of cancer and normal gene expression data. Bioinformatics. Jul. 15. 2005;21(14):3114-3121. BKG, EXC2. [pmid: 15879455].
356 Qu KZ, Zhang K, Li H, et al. Circulating microRNAs as biomarkers for hepatocellular carcinoma. J Clin Gastroenterol. Apr. 2011;45(4):355-360. EXC1. [pmid: 21278583].
357 Rae JM, Creighton CJ, Meck JM, et al. MDA-MB-435 cells are derived from M14 melanoma cells--a loss for breast cancer, but a boon for melanoma research. Breast Cancer Res Treat. Jul. 2007;104(1):13-19. EXC1. [pmid: 17004106].
358 Ramaswamy S, Tamayo P, Rifkin R, et al. Multiclass cancer diagnosis using tumor gene expression signatures. Proc Natl Acad Sci U S A. Dec. 18. 2001;98(26):15149-15154. EXC1. [pmid: 11742071].
359 Ravi V, Wong MK. Strategies and methodologies for identifying molecular targets in sarcomas and other tumors. Curr Treat Options Oncol. Nov. 2005;6(6):487-497. EXC1. [pmid: 16242053].
360 Reicher S, Boyar FZ, Albitar M, et al. Fluorescence in situ hybridization and K-ras analyses improve diagnostic yield of endoscopic ultrasound-guided fine-needle aspiration of solid pancreatic masses. Pancreas. 2011;40(7):1057-1062. EXC1. [pmid: 21705950].
361 Rice D, Kim HW, Sabichi A, et al. The risk of second primary tumors after resection of stage I nonsmall cell lung cancer. Ann Thorac Surg. 2003:1001-1007. discussion 7-8. EXC1. [pmid: 14529975].
362 Ridgeway AG, McMenamin J, Leder P. P53 levels determine outcome during beta-catenin tumor initiation and metastasis in the mammary gland and male germ cells. Oncogene. Jun. 15. 2006;25(25):3518-3527. EXC1. [pmid: 16434961].
363 Ring BZ, Ross DT. Microarrays and molecular markers for tumor classification. Genome Biol. 2002;3(5). comment2005. EXC2. [pmid: 12049658].
364 Rivera E, Holmes FA, Buzdar AU, et al. Fluorouracil, doxorubicin, and cyclophosphamide followed by tamoxifen as adjuvant treatment for patients with stage IV breast cancer with no evidence of disease. Breast J. 2002:2-9. EXC1. [pmid: 11856154].
365 Robertson J, Buzdar A, Nabholtz J, et al. Anastrazole (ArimidexTM) versus tamoxifen as first-line therapy for advanced breast cancer (ABC) in post-menopausal (PM) women - Prospective combined analysis from two international trials. 2nd European Breast Cancer Conference. 2000. EXC1.
366 Robertson JF, Nicholson RI, Bundred NJ, et al. Comparison of the short-term biological effects of 7alpha-[9-(4,4,5,5,5-pentafluoropentylsulfinyl)-nonyl]estra-1,3,5, (10)-triene-3,17beta-diol (Faslodex) versus tamoxifen in postmenopausal women with primary breast cancer. Cancer Res. 2001:6739-6746. EXC1. [pmid: 11559545].
367 Robertson JF, Odling-Smee W, Holcombe C, et al. Pharmacokinetics of a single dose of fulvestrant prolonged-release intramuscular injection in postmenopausal women awaiting surgery for primary breast cancer. Clin Ther. 2003:1440-1452. EXC1. [pmid: 12867220].
368 Rocken C, Lendeckel U, Dierkes J, et al. The number of lymph node metastases in gastric cancer correlates with the angiotensin I-converting enzyme gene insertion/deletion polymorphism. Clin Cancer Res. Apr. 1. 2005;11(7):2526-2530. EXC1. [pmid: 15814629].
369 Rose C, Vtoraya O, Pluzanska A, et al. An open randomised trial of second-line endocrine therapy in advanced breast cancer. comparison of the aromatase inhibitors letrozole and anastrozole. Eur J Cancer. 2003:2318-2327. EXC1. [pmid: 14556923].
370 Ross DT, Scherf U, Eisen MB, et al. Systematic variation in gene expression patterns in human cancer cell lines. Nat Genet. Mar. 2000;24(3):227-235. EXC1. [pmid: 10700174].
371 Roth V, Lange T. Bayesian class discovery in microarray datasets. IEEE Trans Biomed Eng. May. 2004;51(5):707-718. BKG, EXC1. [pmid: 15132496].
372 Rothenstein J, Cleary SP, Pond GR, et al. Neuroendocrine tumors of the gastrointestinal tract: a decade of experience at the Princess Margaret Hospital. Am J Clin Oncol. 2008:64-70. EXC1. [pmid: 18376230].
373 Sadri K, Ren Q, Zhang K, et al. PET imaging of EGFR expression in nude mice bearing MDA-MB-468, a human breast adenocarcinoma. Nucl Med Commun. Jul. 2011;32(7):563-569. EXC1. [pmid: 21572364].
374 Sandberg AA, Bridge JA. Updates on cytogenetics and molecular genetics of bone and soft tissue tumors: Ewing sarcoma and peripheral primitive neuroectodermal tumors. Cancer Genet Cytogenet. Nov. 2000;123(1):1-26. hand search, EXC2. [pmid: 11120329].
375 Sanders HR, Li HR, Bruey JM, et al. Exon scanning by reverse transcriptase-polymerase chain reaction for detection of known and novel EML4-ALK fusion variants in non-small cell lung cancer. Cancer Genet. Jan. 2011;204(1):45-52. EXC1. [pmid: 21356191].
376 Sausville EA. Target selection issues in drug discovery and development. J Chemother. Nov. Suppl 4. 2004;16:16-18. EXC1. [pmid: 15688602].
377 Sausville EA. Optimizing target selection and development strategy in cancer treatment: the next wave. Curr Med Chem Anticancer Agents. Sep. 2004;4(5):445-447. EXC1. [pmid: 15379701].
378 Schniederjan MJ, Shehata B, Brat DJ, et al. De novo germline TP53 mutation presenting with synchronous malignancies of the central nervous system. Pediatr Blood Cancer. Dec. 15. 2009;53(7):1352-1354. EXC1. [pmid: 19711436].
379 Schultz IJ, Wester K, Straatman H, et al. Prediction of recurrence in Ta urothelial cell carcinoma by real-time quantitative PCR analysis: a microarray validation study. Int J Cancer. Oct. 15. 2006;119(8):1915-1919. EXC1. [pmid: 16721812].
380 Segara D, Biankin AV, Kench JG, et al. Expression of HOXB2, a retinoic acid signaling target in pancreatic cancer and pancreatic intraepithelial neoplasia. Clin Cancer Res. May. 1. 2005;11(9):3587-3596. EXC1. [pmid: 15867264].
381 Sekulic A, Haluska P Jr, Miller AJ, et al. Malignant Melanoma in the 21st Century: The Emerging Molecular Landscape. Mayo Clin Proc. 2008;83(7):825-846. EXC1. [pmid: 18613999].
382 Serrano J, Goebel SU, Peghini PL, et al. Alterations in the p16INK4a/CDKN2A tumor suppressor gene in gastrinomas. J Clin Endocrinol Metab. Nov. 2000;85(11):4146-4156. EXC1. [pmid: 11095446].
383 Shankavaram UT, Reinhold WC, Nishizuka S, et al. Transcript and protein expression profiles of the NCI-60 cancer cell panel: an integromic microarray study. Mol Cancer Ther. Mar. 2007;6(3):820-832. BKG, EXC1. [pmid: 17339364].
384 Sharma K, Mohanti BK, Rath GK. Malignant melanoma: a retrospective series from a regional cancer center in India. J Cancer Res Ther. Jul-Sep. 2009;5(3):173-180. EXC1. [pmid: 19841558].
385 Sharman MJ, Volek JS. Weight loss leads to reductions in inflammatory biomarkers after a very-low-carbohydrate diet and a low-fat diet in overweight men. Clin Sci. 2004:365-369. EXC1. [pmid: 15265001].
386 Shedden KA, Taylor JM, Giordano TJ, et al. Accurate molecular classification of human cancers based on gene expression using a simple classifier with a pathological tree-based framework. Am J Pathol. Nov. 2003;163(5):1985-1995. EXC1. [pmid: 14578198].
387 Sheikholeslami MR, Jilani I, Keating M, et al. Variations in the detection of ZAP-70 in chronic lymphocytic leukemia: Comparison with IgV(H) mutation analysis. Cytometry B Clin Cytom. Jul. 15. 2006;70(4):270-275. EXC1. [pmid: 16906585].
388 Shen D, Chang HR, Chen Z, et al. Loss of annexin A1 expression in human breast cancer detected by multiple high-throughput analyses. Biochem Biophys Res Commun. Jan. 7. 2005;326(1):218-227. EXC1. [pmid: 15567174].
389 Shen J, Ambrosone CB, Zhao H. Novel genetic variants in microRNA genes and familial breast cancer. Int J Cancer. Mar. 1. 2009;124(5):1178-1182. EXC1. [pmid: 19048628].
390 Sheng Q, Moreau Y, De Moor B. Biclustering microarray data by Gibbs sampling. Bioinformatics. Oct. Suppl 2. 2003;19:ii196-ii205. BKG, EXC1. [pmid: 14534190].
391 Shevade SK, Keerthi SS. A simple and efficient algorithm for gene selection using sparse logistic regression. Bioinformatics. Nov. 22. 2003;19(17):2246-2253. BKG, EXC1. [pmid: 14630653].
392 Shi Y, Gera J, Lichtenstein A. Interleukin-6 (IL-6) Enhances C-MYC Translation in Multiple Myeloma (MM) Cells: Role of IL-6-Induced Effects on the C-MYC RNA-Binding Poretin, HNRNPA1. Blood. Nov. 20. 2009;114(22):1477. EXC1. [pmid: 19549988].
393 Shi Y, Kanaani J, Menard-Rose V, et al. Increased expression of GAD65 and GABA in pancreatic beta-cells impairs first-phase insulin secretion. Am J Physiol Endocrinol Metab. Sep. 2000;279(3):E684-E694. EXC1. [pmid: 10950838].
394 Sieber O, Heinimann K, Tomlinson I. Genomic stability and tumorigenesis. Semin Cancer Biol. Feb. 2005;15(1):61-66. EXC1. [pmid: 15613289].
395 Simpson PT, Vargas A-C, Al-Ejeh F, et al. Application of molecular findings to the diagnosis and management of breast disease: recent advances and challenges. Hum Pathol. 2011;42(2):153-165. EXC1. [pmid: 21106225].
396 Singer CF, Hudelist G, Fuchs E-M, et al. Incomplete surgical resection of ductal carcinomas in situ results in activation of ERBB2 in residual breast cancer cells. Endocrine-Related Cancer. Mar. 2009;16(1):73-83. EXC1. [pmid: 18948375].
397 Singh D, Chaturvedi R. Recent patents on genes and gene sequences useful for developing breast cancer detection systems. Recent Pat DNA Gene Seq. 2009;3(2):139-147. EXC1. [pmid: 19519584].
398 Sivell S, Iredale R, Gray J, et al. Cancer genetic risk assessment for individuals at risk of familial breast cancer. Cochrane Database of Systematic Reviews. 2007. EXC1.
399 Slovak ML, Bedell V, Hsu YA, et al. Molecular karyotypes of Hodgkin and Reed-Sternberg cells at disease onset reveal distinct copy number alterations in chemosensitive versus refractory Hodgkin lymphoma. Clin Cancer Res. 2011;17(10):3443-3454. EXC1. [pmid: 21385932].
400 Smith SA, Richards WE, Caito K, et al. BRCA1 germline mutations and polymorphisms in a clinic-based series of ovarian cancer cases: A Gynecologic Oncology Group study. Gynecol Oncol. December. 2001;83(3):586-592. EXC1. [pmid: 11733976].
401 Smolen JS, Kay J, Doyle MK, et al. Golimumab in patients with active rheumatoid arthritis after treatment with tumour necrosis factor alpha inhibitors (GO-AFTER study): a multicentre, randomised, double-blind, placebo-controlled, phase III trial. Lancet. 2009:210-221. EXC1. [pmid: 19560810].
402 Soesan M, de Snoo F, Westerga J, et al. Microarray analysis as a helpful tool in identifying the primary tumour in cancer with an unknown primary site. Neth J Med. Jan. 2010;68(1):50-51. EXC4. [pmid: 20103826].
403 Sontrop HM, Moerland PD, van den Ham R, et al. A comprehensive sensitivity analysis of microarray breast cancer classification under feature variability. BMC Bioinformatics. 2009;10:389. EXC1. [pmid: 19941644].
404 Söreide JA, Varhaug JE, Fjösne HE, et al. Adjuvant endocrine treatment (goserelin vs tamoxifen) in pre-menopausal patients with operable node positive stage II breast cancer. A prospective randomized national multicenter study. Eur J Surg Oncol. 2002:505-510. EXC1. [pmid: 12217302].
405 Speel EJ, van de Wouw AJ, Claessen SM, et al. Molecular evidence for a clonal relationship between multiple lesions in patients with unknown primary adenocarcinoma. Int J Cancer. Sep. 15. 2008;123(6):1292-1300. EXC1. [pmid: 18561313].
406 Stahl M, Stuschke M, Lehmann N, et al. Chemoradiation with and without surgery in patients with locally advanced squamous cell carcinoma of the esophagus. J Clin Oncol. 2005:2310-2317. EXC1. [pmid: 15800321].
407 Stahl M, Walz MK, Stuschke M, et al. Phase III comparison of preoperative chemotherapy compared with chemoradiotherapy in patients with locally advanced adenocarcinoma of the esophagogastric junction. J Clin Oncol. 2009:851-856. EXC1. [pmid: 19139439].
408 Statnikov A, Aliferis CF, Tsamardinos I, et al. A comprehensive evaluation of multicategory classification methods for microarray gene expression cancer diagnosis. Bioinformatics. Mar. 1. 2005;21(5):631-643. BKG, EXC1. [pmid: 15374862].
409 Staub E, Buhr HJ, Grone J. Predicting the site of origin of tumors by a gene expression signature derived from normal tissues. Oncogene. Aug. 5. 2010;29(31):4485-4492. EXC1. [pmid: 20514016].
410 Staunton JE, Slonim DK, Coller HA, et al. Chemosensitivity prediction by transcriptional profiling. Proc Natl Acad Sci U S A. Sep. 11. 2001;98(19):10787-10792. EXC1. [pmid: 11553813].
411 Stevens EV, Nishizuka S, Antony S, et al. Predicting cisplatin and trabectedin drug sensitivity in ovarian and colon cancers. Mol Cancer Ther. Jan. 2008;7(1):10-18. EXC1. [pmid: 18187810].
412 Stokes A. Comment on "Oral Oncology editorial--Continued misrepresentation of KB cells as being of oral cancer phenotype requires action" [O’Neill ID. Oral Oncol 2009; 45(10):e117-118]. Oral Oncol. May. 2010;46(5):e38. EXC1. [pmid: 20338802].
413 Stremmel C, Wein A, Hohenberger W, et al. DNA microarrays: a new diagnostic tool and its implications in colorectal cancer. Int J Colorectal Dis. May. 2002;17(3):131-136. EXC1. [pmid: 12049305].
414 Suarez C, Rodrigo JP, Ferlito A, et al. Tumours of familial origin in the head and neck. Oral Oncol. Nov. 2006;42(10):965-978. EXC1. [pmid: 16857415].
415 Sukhai MA, Li X, Hurren R, et al. The Anti-Malarial Mefloquine Demonstrates Preclinical Activity In Leukemia and Myeloma, and Is Dependent Upon Toll-Like Receptor Signaling for Its Cytotoxicity. Blood. Nov. 19. 2010;116(21):132. EXC1.
416 Sun Y, Goodison S, Li J, et al. Improved breast cancer prognosis through the combination of clinical and genetic markers. Bioinformatics. Jan. 1. 2007;23(1):30-37. EXC1. [pmid: 17130137].
417 Surguladze D, Steiner P, Prewett M, et al. Methods for evaluating effects of an irinotecan + 5-fluorouracil/leucovorin (IFL) regimen in an orthotopic metastatic colorectal cancer model utilizing in vivo bioluminescence imaging. Methods Mol Biol. 2010;602:235-252. EXC1. [pmid: 20012402].
418 Szczepanski T, De Ridder D, Van der Velden VHJ, et al. Comparative analysis of gene expression profiles between diagnosis and relapse of childhood acute lymphoblastic leukemia. Blood. Nov. 16. 2007;110(11, Part 1):826A. EXC1.
419 Tainsky MA. Genomic and proteomic biomarkers for cancer: A multitude of opportunities. 2009. http://www.sciencedirect.com/science?_ob=GatewayURL&_origin=ScienceSearch&_method=citationSearch&_piikey=S0304419X09000262&_version=1&_returnURL=http%3A%2F%2Fwww.scirus.com%2Fsrsapp%2F&md5=109ac9d221338307f01b1290ccbac18c1796. EXC1.
420 Takahashi H, Kobayashi T, Honda H. Construction of robust prognostic predictors by using projective adaptive resonance theory as a gene filtering method. Bioinformatics. Jan. 15. 2005;21(2):179-186. EXC1. [pmid: 15308545].
421 Takahashi T, Kazama Y, Shimizu H, et al. Brain metastases of malignant melanoma showing unbalanced whole arm chromosomal translocations der (8; 14) (q10; q10) and der (11; 15) (q10; q10) in a Japanese patient. Intern Med. Sep. 2001;40(9):956-960. EXC1. [pmid: 11579965].
422 Talantov D, Baden J, Jatkoe T, et al. Quantitative reverse transcriptase-polymerase chain reaction assay to identify metastatic carcinoma tissue of origin. J Mol Diagn. Jul. 2006;8(3):320-329. EXC1. [pmid: 16825504].
423 Talbot SG, Estilo C, Maghami E, et al. Gene expression profiling allows distinction between primary and metastatic squamous cell carcinomas in the lung. Cancer Res. Apr. 15. 2005;65(8):3063-3071. EXC1. [pmid: 15833835].
424 Tang C, Chua CL, Ang BT. Insights into the cancer stem cell model of glioma tumorigenesis. Ann Acad Med Singapore. May. 2007;36(5):352-357. EXC1. [pmid: 17549283].
425 Tang W, Hu Z, Muallem H, et al. Quality Assurance of RNA Expression Profiling in Clinical Laboratories. J Mol Diagn. 2011. In Press, Uncorrected Proof. EXC1.
426 Thompson IM, Tangen CM, Paradelo J, et al. Adjuvant radiotherapy for pathologically advanced prostate cancer: a randomized clinical trial. J Am Med Assoc. 2006:2329-2335. EXC1.
427 Tieszen CR, Goyeneche AA, Brandhagen BN, et al. Antiprogestin mifepristone inhibits the growth of cancer cells of reproductive and non-reproductive origin regardless of progesterone receptor expression. BMC Cancer. 2011;11:207. EXC1. [pmid: 21619605].
428 Timar J, Hegedus B, Raso E. KRAS Mutation Testing of Colorectal Cancer for Anti-EGFR Therapy: Dogmas Versus Evidence. Current Cancer Drug Targets. Dec. 2010;10(8):813-823. EXC1. [pmid: 20718705].
429 Tirado CA, Meloni-Ehrig AM, Edwards T, et al. Cryptic ins(4;11)(q21;q23q23) detected by fluorescence in situ hybridization: a variant of t(4;11)(q21;q23) in an infant with a precursor B-cell acute lymphoblastic leukemia report of a second case. Cancer Genet Cytogenet. 2007;174(2):166-169. BKG, EXC2. [pmid: 17452260].
430 Tong KB, Hubert HB, Santry B, et al. Incidence, costs of care and survival of Medicare beneficiaries diagnosed with carcinoma of unknown primary origin. Annual meeting of the American Society of Clinical Oncology. 2006 June 2–6. Atlanta, GA. hand search, EXC1.
431 Tothill RW, Kowalczyk A, Rischin D, et al. An expression-based site of origin diagnostic method designed for clinical application to cancer of unknown origin. Cancer Res. May. 15. 2005;65(10):4031-4040. EXC1. [pmid: 15899792].
432 Tracey L, Villuendas R, Dotor AM, et al. Mycosis fungoides shows concurrent deregulation of multiple genes involved in the TNF signaling pathway: an expression profile study. Blood. Aug. 1. 2003;102(3):1042-1050. EXC1. [pmid: 12689942].
433 Tsuchiya T, Okaji Y, Tsuno NH, et al. Targeting Id1 and Id3 inhibits peritoneal metastasis of gastric cancer. Cancer Sci. Nov. 2005;96(11):784-790. EXC1. [pmid: 16271072].
434 Umetani N, Mori T, Koyanagi K, et al. Aberrant hypermethylation of ID4 gene promoter region increases risk of lymph node metastasis in T1 breast cancer. Oncogene. Jul. 7. 2005;24(29):4721-4727. EXC1. [pmid: 15897910].
435 Unidad de Evaluacion de Tecnologias Sanitarias Agencia Lain E. Effectiveness of colorectal cancer screening in asymptomatic patients of colorectal cancer. Genetics tests (Brief record). Madrid. Unidad de Evaluacion de Tecnologias Sanitarias Agencia Lain Entralgo (UETS). 2005. EXC1.
436 van Houte BP, Heringa J. Accurate confidence aware clustering of array CGH tumor profiles. Bioinformatics. Jan. 1. 2010;26(1):6-14. BKG, EXC1. [pmid: 19846437].
437 van Laar RK, Ma XJ, de Jong D, et al. Implementation of a novel microarray-based diagnostic test for cancer of unknown primary. Int J Cancer. Sep. 15. 2009;125(6):1390-1397. EXC1. [pmid: 19536816].
438 van Sprundel TC, Schmidt MK, Rookus MA, et al. Risk reduction of contralateral breast cancer and survival after contralateral prophylactic mastectomy in BRCA1 or BRCA2 mutation carriers. Br J Cancer. Aug. 8. 2005;93(3):287-292. EXC1. [pmid: 16052221].
439 van Waarde A, Rybczynska AA, Ramakrishnan N, et al. Sigma receptors in oncology: therapeutic and diagnostic applications of sigma ligands. Curr Pharm Des. 2010;16(31):3519-3537. EXC1. [pmid: 21050178].
440 Vang R, Gown AM, Farinola M, et al. p16 expression in primary ovarian mucinous and endometrioid tumors and metastatic adenocarcinomas in the ovary: Utility for identification of metastatic HPV-related endocervical adenocarcinomas. Am J Surg Pathol. 2007;31(5):653-663. EXC1. [pmid: 17460447].
441 Varadhachary GR, Raber MN. Gene expression profiling in cancers of unknown primary. J Clin Oncol. Sep. 1. 2009;27(25):e85-e86. author reply e7-8. BKG at FT Stage. [pmid: 19635993].
442 Varadhachary GR, Talantov D, Raber MN, et al. Molecular profiling of carcinoma of unknown primary and correlation with clinical evaluation. J Clin Oncol. Sep. 20. 2008;26(27):4442-4448. EXC1. [pmid: 18802157].
443 Vazina A, Baniel J, Yaacobi Y, et al. The rate of the founder Jewish mutations in BRCA1 and BRCA2 in prostate cancer patients in Israel. Eur J Cancer. July. Supplement 2. 2000;36:463-466. EXC1Biosis Previews.
444 Verhaak RG, Staal FJ, Valk PJ, et al. The effect of oligonucleotide microarray data pre-processing on the analysis of patient-cohort studies. BMC Bioinformatics. 2006;7:105. EXC1. [pmid: 16512908].
445 Wang D, Lv Y, Guo Z, et al. Effects of replacing the unreliable cDNA microarray measurements on the disease classification based on gene expression profiles and functional modules. Bioinformatics. Dec. 1. 2006;22(23):2883-2889. BKG, EXC1. [pmid: 16809389].
446 Wang H, Azuaje F, Black N. Improving biomolecular pattern discovery and visualization with hybrid self-adaptive networks. IEEE Trans Nanobioscience. Dec. 2002;1(4):146-166. EXC1. [pmid: 16689206].
447 Wang JY, Yeh CS, Chen YF, et al. Development and evaluation of a colorimetric membrane-array method for the detection of circulating tumor cells in the peripheral blood of Taiwanese patients with colorectal cancer. Int J Mol Med. May. 2006;17(5):737-747. EXC1. [pmid: 16596255].
448 Wang P-H, Shyong W-Y, Li YF, et al. BRCA1 mutations in Taiwanese with epithelial ovarian carcinoma and sporadic primary serous peritoneal carcinoma. Jpn J Clin Oncol. August. 2000;30(8):343-348. EXC1. [pmid: 11059339].
449 Wasif N, Faries MB, Saha S, et al. Predictors of occult nodal metastasis in colon cancer: results from a prospective multicenter trial. Surgery. 2010:352-357. EXC1. [pmid: 20116081].
450 Watanabe T, Kobunai T, Toda E, et al. Gene expression signature and the prediction of ulcerative colitis-associated colorectal cancer by DNA microarray. Clin Cancer Res. Jan. 15. 2007;13(2 Pt 1):415-420. EXC1. [pmid: 17255260].
451 Weichert W. HDAC expression and clinical prognosis in human malignancies. Cancer Lett. Aug. 8. 2009;280(2):168-176. EXC1. [pmid: 19103471].
452 Weichert W, Schmidt M, Gekeler V, et al. Polo-like kinase 1 is overexpressed in prostate cancer and linked to higher tumor grades. Prostate. Aug. 1. 2004;60(3):240-245. EXC1. [pmid: 15176053].
453 Weitzel JN, Lagos V, Blazer KR, et al. Prevalence of BRCA mutations and founder effect in high-risk Hispanic families. Cancer Epidemiol Biomarkers Prevent. Jul. 2005;14(7):1666-1671. EXC1.
454 Wester HJ, Schottelius M, Scheidhauer K, et al. PET imaging of somatostatin receptors: design, synthesis and preclinical evaluation of a novel 18F-labelled, carbohydrated analogue of octreotide. Eur J Nucl Med Mol Imaging. Jan. 2003;30(1):117-122. EXC1. [pmid: 12483418].
455 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. EXC1. [pmid: 14606960].
456 Williamson SR, Zhang S, Yao JL, et al. ERG-TMPRSS2 rearrangement is shared by concurrent prostatic adenocarcinoma and prostatic small cell carcinoma and absent in small cell carcinoma of the urinary bladder: evidence supporting monoclonal origin. Mod Pathol. Aug. 2011;24(8):1120-1127. EXC1. [pmid: 21499238].
457 Wilson JW, Deed RW, Inoue T, et al. Expression of Id helix-loop-helix proteins in colorectal adenocarcinoma correlates with p53 expression and mitotic index. Cancer Res. Dec. 15. 2001;61(24):8803-8810. EXC1. [pmid: 11751402].
458 Wilson MJ, Sellers RG, Wiehr C, et al. Expression of matrix metalloproteinase-2 and-9 and their inhibitors, tissue inhibitor of metalloproteinase-1 and-2, in primary cultures of human prostatic stromal and epithelial cells. J Cell Physiol. May. 2002;191(2):208-216. EXC1. [pmid: 12064464].
459 Wittmann J, Jack HM. Serum microRNAs as powerful cancer biomarkers. Biochim Biophys Acta. Dec. 2010;1806(2):200-207. EXC2. [pmid: 20637263].
460 Wong AS, Pelech SL, Woo MM, et al. Coexpression of hepatocyte growth factor-Met: an early step in ovarian carcinogenesis?. Oncogene. Mar. 15. 2001;20(11):1318-1328. EXC1. [pmid: 11313876].
461 Wong JC, Chan SK, Suh KW, et al. Downregulation of MMP-2 is predictive of local recurrence and distant metastasis in colorectal cancer. Gastroenterology. May. 2009;136(5, Suppl. 1):A748. Biosis Previews, EXC1.
462 Worley LA, Long MD, Onken MD, et al. Micro-RNAs associated with metastasis in uveal melanoma identified by multiplexed microarray profiling. Melanoma Res. Jun. 2008;18(3):184-190. EXC1. [pmid: 18477892].
463 Wu M, Yuan S, Szporn AH, et al. Immunocytochemical detection of XIAP in body cavity effusions and washes. Mod Pathol. Dec. 2005;18(12):1618-1622. EXC1. [pmid: 16118627].
464 Xu R, Feiner H, Li P, et al. Differential Amplification and Overexpression of HER-2/neu, p53, MIB1, and Estrogen Receptor/Progesterone Receptor among Medullary Carcinoma, Atypical Medullary Carcinoma, and High-Grade Invasive Ductal Carcinoma of Breast. Arch Pathol Lab Med. 2003;127(11):1458-1464. EXC1. [pmid: 14567723].
465 Yang H, Tamayo R, Almonte M, et al. Clinical significance of MUC1, MUC2 and CK17 expression patterns for diagnosis of pancreatobiliary carcinoma. Biotech Histochem. 2011. Mar. 28. EXC1. [pmid: 21438791].
466 Yap WN, Zaiden N, Tan YL, et al. Id1, inhibitor of differentiation, is a key protein mediating anti-tumor responses of gamma-tocotrienol in breast cancer cells. Cancer Lett. May. 28. 2010;291(2):187-199. EXC1. [pmid: 19926394].
467 Yaren A, Turgut S, Kursunluoglu R, et al. Association between the polymorphism of the angiotensin-converting enzyme gene and tumor size of breast cancer in premenopausal patients. Tohoku J Exp Med. Oct. 2006;210(2):109-116. EXC1. [pmid: 17023764].
468 Yasmeen A, Bismar TA, Kandouz M, et al. E6/E7 of HPV type 16 promotes cell invasion and metastasis of human breast cancer cells. Cell Cycle. Aug. 15. 2007;6(16):2038-2042. EXC1. [pmid: 17721085].
469 Yeh CH, Abdool A, Bruey JM. Plasma tyrosine kinase activity as a potential biomarker in BCR-ABL1-targeted therapy. Cancer Biomarkers. 2010;7(6):295-303. EXC1. [pmid: 21694468].
470 Yilmaz M, Christofori G, Lehembre F. Distinct mechanisms of tumor invasion and metastasis. Trends Mol Med. Dec. 2007;13(12):535-541. EXC2. [pmid: 17981506].
471 Zakharkin S, Page G, Allison D, et al. Gene expression profiling in pediatric brain tumors using microarray analysis. FASEB J. May. 14. Suppl. S. 2004;18(8):C101-C102. EXC2.
472 Zhang B, Beck AH, Taube JM, et al. Combined use of PCR-based TCRG and TCRB clonality tests on paraffin-embedded skin tissue in the differential diagnosis of mycosis fungoides and inflammatory dermatoses. J Mol Diagn. May. 2010;12(3):320-327. EXC1. [pmid: 20203005].
473 Zhang Q, Fan H, Shen J, et al. Human breast cancer cell lines co-express neuronal, epithelial, and melanocytic differentiation markers in vitro and in vivo. PLoS One. 2010;5(3):e9712. EXC1. [pmid: 20300523].
474 Zhou X, Liu KY, Wong ST. Cancer classification and prediction using logistic regression with Bayesian gene selection. J Biomed Inform. Aug. 2004;37(4):249-259. BKG, Exc1. [pmid: 15465478].
475 Zhou YP, Pena JC, Roe MW, et al. Overexpression of Bcl-x(L) in beta-cells prevents cell death but impairs mitochondrial signal for insulin secretion. Am J Physiol Endocrinol Metab. Feb. 2000;278(2):E340-E351. EXC1. [pmid: 10662719].