# Quality Assessment Ratings of Studies

Title (Year) | KQ2 and KQ3 | KQ4
Barr (1995)1 | G | NA
Beck (2011)2 | G | F
Bridge (2006)3 | F | F
Delattre (1994)4 | F | F
Dumur (2008)5 | G | NA
Dumur (2008) Assessing the impact of tumor devitalization time (poster)6 | F | NA
Dumur (2008) Clinical verification of the Pathwork TOO Test (abstract)7 | G | NA
Erlander (2011)8 | G | NA
Gamberi (2011)9 | F | NA
Greco (2010)10 | G | NA
Grenert (2011)11 | G | NA
Hainsworth, Pillai et al. (2011)12 | NA | G
Hainsworth, Schnabel et al. (2011)13 | NA | F
Hainsworth, Spigel et al. (2010) (poster)14 | NA | G
Hornberger (2012)15 | NA | F
Kerr (2012)16 | G | NA
Lae (2002)17 | G | NA
Laouri (2010)18 | NA | F
Lewis (2007)19 | G | NA
Ma (2006)20 | G | NA
Mhawech-Fauceglia (2006)21 | G | NA
Monzon (2009)22 | G | NA
Monzon (2010)23 | G | NA
Mueller (2011)24 | F | F
Pantou (2003)25 | NA | G
Patel (2005)26 | G | NA
Pillai (2010)27 | G | NA
Rosenfeld (2008)28 | G | NA
Rosenwald (2010)29 | G | NA
Stancel (2011)30 | G | G
Varadhachary (2011)31 | G | G
Wu (2010)32 | G | NA
Yamaguchi (2005)33 | F | NA
Dumur (2011)34 | G | NA
Greco (2012)35 | NA | F
Kerr (2012)36 | G | NA
Lal (2012)37 | G | NA
Laouri (2011)38 | NA | F
McGee (2011)39 | NA | F
Pollen (2011)40 | NA | F
Schroeder (2012)41 | NA | F
Wu (2012)42 | G | NA
Nystrom (2012)43 | NA | G
Meiri (2012)44 | G | F
Azueta (2012)45 | G | NA
Hainsworth (2012)46 | NA | F
Kulkarni (2012)47 | G | NA
Pavlidis (2012)48 | NA | G
Thompson (2011)49 | NA | F
Weiss (2012)50 | G | G

## References

1 Barr FG, Chatten J, D'Cruz CM, et al. Molecular assays for chromosomal translocations in the diagnosis of pediatric soft tissue sarcomas. JAMA. Feb. 15. 1995;273(7):553-557. [pmid: 7530783].
2 Beck AH, Rodriguez-Paris J, Zehnder J, et al. Evaluation of a gene expression microarray-based assay to determine tissue type of origin on a diverse set of 49 malignancies. Am J Surg Pathol. Jul. 2011;35(7):1030-1037. [pmid: 21602661].
3 Bridge RS, Rajaram V, Dehner LP, et al. Molecular diagnosis of Ewing sarcoma/primitive neuroectodermal tumor in routinely processed tissue: a comparison of two FISH strategies and RT-PCR in malignant round cell tumors. Mod Pathol. Jan. 2006;19(1):1-8. [pmid: 16258512].
4 Delattre O, Zucman J, Melot T, et al. The Ewing family of tumors--a subgroup of small-round-cell tumors defined by specific chimeric transcripts. N Engl J Med. Aug. 4. 1994;331(5):294-299. [pmid: 8022439].
5 Dumur CI, Lyons-Weiler M, Sciulli C, et al. Interlaboratory performance of a microarray-based gene expression test to determine tissue of origin in poorly differentiated and undifferentiated cancers. J Mol Diagn. Jan. 2008;10(1):67-77. [pmid: 18083688].
6 Dumur CI, Ladd A, Ferreira-Gonzalez A, et al. Assessing the impact of tumor devitalization time on gene expression-based tissue of origin testing. Association for Molecular Pathology. 2008 October 29 - November 2. Grapevine, TX.
7 Dumur CI, Blevins TL, Schaum JC, et al. Clinical verification of the Pathwork Tissue of Origin Test on poorly differentiated metastases. Association for Molecular Pathology. 2008 October 29 – November 2. Grapevine, TX.
8 Erlander MG, Ma X-J, Kesty NC, et al. Performance and Clinical Evaluation of the 92-Gene Real-Time PCR Assay for Tumor Classification. The Journal of Molecular Diagnostics. 2011;13(5):493-503. [pmid: 21708287].
9 Gamberi G, Cocchi S, Benini S, et al. Molecular diagnosis in ewing family tumors the rizzoli experience-222 consecutive cases in four years. J Mol Diagn. 2011;13(3):313-324. [pmid: 21458383].
10 Greco FA, Spigel DR, Yardley DA, et al. Molecular profiling in unknown primary cancer: accuracy of tissue of origin prediction. Oncologist. 2010;15(5):500-506. [pmid: 20427384].
11 Grenert JP, Smith A, Ruan W, et al. Gene expression profiling from formalin-fixed, paraffin-embedded tissue for tumor diagnosis. Clin Chim Acta. Jul. 15. 2011;412(15–16):1462-1464. [pmid: 21497155].
12 Hainsworth J, Pillai R, Henner DW, et al. Molecular tumor profiling in the diagnosis of patients with carcinoma of unknown primary site: retrospective evaluation of gene microarray assay. J Molec Bio and Diagn. 2011. June. 27.
13 Hainsworth JD, Schnabel CA, Erlander MG, et al. A retrospective study of treatment outcomes in patients with carcinoma of unknown primary site and a colorectal cancer molecular profile. Clin Colorectal Cancer. Jun. 2012;11(2):112-118. [pmid: 22000811].
14 Hainsworth JD, Spigel DR, Rubin M, et al. Treatment of Carcinoma of Unknown Primary Site (CUP) Directed by Molecular Profiling Diagnosis: A Prospective, Phase II Trial. American Society of Clinical Oncology Annual Meeting. 2010. June. Abstract #10540.
15 Hornberger JD I. Cost Effectiveness of Gene Expression Profiling for Tumor Site Origin. AACR IASLC Joint Conference on Molecular Origins of Lung Cancer: Biology, Therapy, and Personalized Medicine; 2012. January 10, 2012. San Diego, CA.
16 Kerr SE, Schnabel CA, Sullivan PS, et al. Multisite validation study to determine performance characteristics of a 92-gene molecular cancer classifier. Clin Cancer Res. Jul. 15. 2012;18(14):3952-3960. [pmid: 22648269].
17 Lae ME, Roche PC, Jin L, et al. Desmoplastic small round cell tumor: a clinicopathologic, immunohistochemical, and molecular study of 32 tumors. Am J Surg Pathol. Jul. 2002;26(7):823-835. [pmid: 12131150].
18 Laouri M, Nystrom JS, Halks-Miller M, et al. Impact of a Gene Expression-Based Tissue of Origin Test on Diagnosis and Recommendations for First-Line Chemotherapy. ASCO. 2010 June 4–8. Chicago, IL.
19 Lewis TB, Coffin CM, Bernard PS. Differentiating Ewing's sarcoma from other round blue cell tumors using a RT-PCR translocation panel on formalin-fixed paraffin-embedded tissues. Mod Pathol. Mar. 2007;20(3):397-404. [pmid: 17334332].
20 Ma XJ, Patel R, Wang X, et al. Molecular classification of human cancers using a 92-gene real-time quantitative polymerase chain reaction assay. Arch Pathol Lab Med. Apr. 2006;130(4):465-473. [pmid: 16594740].
21 Mhawech-Fauceglia P, Herrmann F, Penetrante R, et al. Diagnostic utility of FLI-1 monoclonal antibody and dual-colour, break-apart probe fluorescence in situ (FISH) analysis in Ewing's sarcoma/primitive neuroectodermal tumour (EWS/PNET). A comparative study with CD99 and FLI-1 polyclonal antibodies. Histopathology. 2006;49(6):569-575. [pmid: 17163841].
22 Monzon FA, Lyons-Weiler M, Buturovic LJ, et al. Multicenter validation of a 1,550-gene expression profile for identification of tumor tissue of origin. J Clin Oncol. May. 20. 2009;27(15):2503-2508. [pmid: 19332734].
23 Monzon FA, Medeiros F, Lyons-Weiler M, et al. Identification of tissue of origin in carcinoma of unknown primary with a microarray-based gene expression test. Diagn Pathol. 2010;5:3. [pmid: 20205775].
24 Mueller WC, Spector Y, Edmonston TB, et al. Accurate classification of metastatic brain tumors using a novel microRNA-based test. Oncologist. 2011;16(2):165-174. [pmid: 21273512].
25 Pantou D, Tsarouha H, Papadopoulou A, et al. Cytogenetic profile of unknown primary tumors: clues for their pathogenesis and clinical management. Neoplasia. Jan-Feb. 2003;5(1):23-31. [pmid: 12659667].
26 Patel RM, Downs-Kelly E, Weiss SW, et al. Dual-color, break-apart fluorescence in situ hybridization for EWS gene rearrangement distinguishes clear cell sarcoma of soft tissue from malignant melanoma. Mod Pathol. Dec. 2005;18(12):1585-1590. [pmid: 16258500].
27 Pillai R, Deeter R, Rigl CT, et al. Validation of a microarray-based gene expression test for tumors with uncertain origins using formalin-fixed paraffin-embedded (FFPE) specimens. J Clin Oncol. 2009;27. suppl abstr e20015.
28 Rosenfeld N, Aharonov R, Meiri E, et al. MicroRNAs accurately identify cancer tissue origin. Nat Biotechnol. Apr. 2008;26(4):462-469. [pmid: 18362881].
29 Rosenwald S, Gilad S, Benjamin S, et al. Validation of a microRNA-based qRT-PCR test for accurate identification of tumor tissue origin. Mod Pathol. Jun. 2010;23(6):814-823. [pmid: 20348879].
30 Stancel GA, Coffey D, Alvarez K, et al. Identification of tissue of origin in body fluid specimens using a gene expression microarray assay. Cancer Cytopathol. 2011. Jun. 29. [pmid: 21717591].
31 Varadhachary GR, Spector Y, Abbruzzese JL, et al. Prospective Gene Signature Study Using microRNA to Identify the Tissue of Origin in Patients with Carcinoma of Unknown Primary. Clin Cancer Res. Jun. 15. 2011;17(12):4063-4070. [pmid: 21531815].
32 Wu AH, Drees JC, Wang H, et al. Gene expression profiles help identify the tissue of origin for metastatic brain cancers. Diagn Pathol. 2010;5:26. [pmid: 20420692].
33 Yamaguchi U, Hasegawa T, Morimoto Y, et al. A practical approach to the clinical diagnosis of Ewing's sarcoma/primitive neuroectodermal tumour and other small round cell tumours sharing EWS rearrangement using new fluorescence in situ hybridisation probes for EWSR1 on formalin fixed, paraffin wax embedded tissue. J Clin Pathol. Oct. 2005;58(10):1051-1056. [pmid: 16189150].
34 Dumur CI, Fuller CE, Blevins TL, et al. Clinical verification of the performance of the pathwork tissue of origin test: utility and limitations. Am J Clin Pathol. Dec. 2011;136(6):924-933. [pmid: 22095379].
35 Greco FA. Cancer of unknown primary site: evolving understanding and management of patients. Clin Adv Hematol Oncol. Aug. 2012;10(8):518-524. [pmid: 23073050].
36 Kerr SE, Schnabel CA, Sullivan PS, et al. Use of a 92-gene molecular classifier to predict the site of origin for primary and metastatic tumors with neuroendocrine differentiation. Lab Invest. 2012;92:147A.
37 Lal A, Panos R, Marjanovic M, et al. A gene expression profile test for the differential diagnosis of ovarian versus endometrial cancers. Oncotarget. Feb. 2012;3(2):212-223. [pmid: 22371431].
38 Laouri M, Halks-Miller M, Henner WD, et al. Potential clinical utility of gene-expression profiling in identifying tumors of uncertain origin. Personalized Medicine. 2011;8(6):615-622.
39 McGee RS, Kesty NC, Erlander MG, et al. Molecular tumor classification using a 92-gene assay in the differential diagnosis of squamous cell lung cancer. Community Oncology. 2011;8(3):123-131.
40 Pollen M, Wellman G, Lowery-Nordberg M. Utility of gene-expression profiling for reporting difficult-to-diagnose cancers. J Mol Diagn. 2011;13(6):764.
41 Schroeder BE, Laouri M, Chen E, et al. Pathological diagnoses in cases of indeterminate or unknown primary submitted for molecular tumor profiling. Lab Invest. 2012;92:105A-106A.
42 Wu F, Huang D, Wang L, et al. 92-gene molecular profiling in identification of cancer origin: A retrospective study in Chinese population and performance within different subgroups. PLoS One. 2012;7(6).
43 Nystrom SJ, Hornberger JC, Varadhachary GR, et al. Clinical utility of gene-expression profiling for tumor-site origin in patients with metastatic or poorly differentiated cancer: impact on diagnosis, treatment, and survival. Oncotarget. Jun. 2012;3(6):620-628. [pmid: 22689213].
44 Meiri E, Mueller WC, Rosenwald S, et al. A second-generation microRNA-based assay for diagnosing tumor tissue origin. Oncologist. 2012;17(6):801-812. [pmid: 22618571].
45 Azueta A, Maiques O, Velasco A, et al. Gene expression microarray-based assay to determine tumor site of origin in a series of metastatic tumors to the ovary and peritoneal carcinomatosis of suspected gynecologic origin. Hum Pathol. 2012. Aug. 30. [pmid: 22939961].
46 Hainsworth JD, Rubin MS, Spigel DR, et al. Molecular Gene Expression Profiling to Predict the Tissue of Origin and Direct Site-Specific Therapy in Patients With Carcinoma of Unknown Primary Site: A Prospective Trial of the Sarah Cannon Research Institute. J Clin Oncol. 2012. Oct. 1. [pmid: 23032625].
47 Kulkarni A, Pillai R, Ezekiel AM, et al. Comparison of histopathology to gene expression profiling for the diagnosis of metastatic cancer. Diagn Pathol. Aug. 21. 2012;7(1):110. [pmid: 22909314].
48 Pavlidis NP G. Accuracy of microRNA-based classification of metastases of unknown primary. J Clin Oncol. suppl abstr 10575. 2012;30:2012.
49 Thompson DSH, J D. Molecular tumor profiling (MTP) in cancer of unknown primary site (CUP): A complement to standard pathologic diagnosis. J Clin Oncol. 2011. May. 20. 2011; Vol 29, No 15_suppl (May 20 Supplement), 2011: 10560(15).
50 Weiss LC P. Blinded comparator study of immunohistochemistry (IHC) versus a 92-gene cancer classifier in the diagnosis of primary site in metastatic tumors. J Clin Oncol. 2012;Vol 30(No 15_suppl). (May 20 Supplement) 2012: e21019.