# Evidence Tables

Table C-1 Study characteristics of included studies

Tissue of Origin Test, Author, Year Study Years, Region | Race/ Ancestry | Age Group of Patients | Age, Median, Range or Distribution | Female, n (%) | Sample Size, N | Cancer/Tumor Types
CancerTypeID Erlander 2011^1^ NS Multinational, U.S. | NR | Multiple age groups | ≥65: 44% Mean (± SD): 62 (13) | 53% | Training dataset: N=2206; Independent sample set: N=187; Clinical cases: N=300 | Adrenal, brain, breast, cervix, cholangiocarcinoma, endometrium, esophagus (squamous cell), gallbladder, gastroesophageal (adenocarcinoma), germ cell, gist, head/neck, intestine, kidney (renal cell carcinoma), liver, lung, lymphoma, melanoma, meningioma, mesothelioma, neuroendocrine, ovary, pancreas, prostate, sarcoma, sex cord stromal tumor, skin, thymus, thyroid, urinary/bladder
CancerTypeID Greco 2010^2^ 2000–2007 U.S. only | NR | Multiple age groups | 25 – 50: 4 50–64: 8 65+: 8 | 11 | 28 | Breast, primary peritoneal, ovary, colon, nonsmall cell lung cancer, gastric, melanoma, pancreas
CancerTypeID Greco 2012^3^ NR U.S. only | NR | | Median: 61 years Range: 46–81 years | 18 | 32 | CUP
CancerTypeID Hainsworth, Schnabel et al. 2011^4^ 3/2008–8/2009 NS NS | NR | Multiple age groups | Median: 57 Range: 35–86 | 27 | 125 | Liver, bone/bone marrow, lymph nodes, peritoneum, lungs, abdominal/ retroperitoneal nodes, uterus/ovary, adrenal glands
CancerTypeID Hainsworth 2010^5^ [Disease] NS NS | NR | Multiple age groups | Median: 64 Range: 26–85 | 33 | 110 | CUP
CancerTypeID Hainsworth 2010^5^ [Survival] NS NS | NR | Multiple age groups | Median: 64 Range: 26–85 | 33 | 110 | CUP
CancerTypeID Hainsworth, 2012^6^ 2008–2011 U.S. only | NR | | Median: 64 Range: 26–89 | 136 | 223 | CUP
CancerTypeID Kerr 2012^7^ NR NR | NR | Multiple age groups | <50: 203 50–64: 271 >64: 316 | 405 | 790 | Metastatic tumors and moderately to poorly differentiated primary tumors of the following types: Adrenal, brain, breast, cervix adenocarcinoma, endometrium, gastroesophageal, germ cell, GIST, head-neck-salivary. Intestine, kidney, liver, lung-adeno/large cell, lymphoma, melanoma, meningioma, mesothelioma, neuroendocrine, ovary, pancreaticobiliary, prostate, sarcoma, sex cord stromal tumor, skin basal cell, squamous, thymus, thyroid, urinary/bladder
CancerTypeID Kerr 2012^8^ NR NR | NR | | NR | NR | 75 | Neuroendocrine carcinoma
CancerTypeID Ma 2006^9^ NR U.S. only | NR | NR | NR | NR | 578 | Adrenal, brain, breast, carcinoid–intestine, cervix–adeno, cervix–squamous, endometrium, gallbladder, germ–cell–ovary, gist (gastrointestinal stromal tumor of stomach), kidney, leiomyosarcoma, liver, lung–adeno–large cell, lung–small, lung–squamous, lymphoma–b cell, lymphoma–Hodgkin, lymphoma–t cell, meningioma, mesothelioma, osteosarcoma, ovary–clear, ovary–serous, pancreas, prostate, skin–basal cell, skin–melanoma, skin–squamous, small and large bowel, soft-tissue–liposarcoma, soft-tissue–mfh, soft-tissue–sarcoma–synovial, stomach–adeno, testis–other, testis–seminoma, thyroid–follicular–papillary, thyroid–medullary, urinary/bladder
CancerTypeID McGee et la, 2011^10^ 2009 U.S. only | NR | | 64 ±13 | 40% | 62 Clinician survey 22 (20 responses) | Squamous cell lung cancer
CancerTypeID Schroder, 2012^11^ NR U.S. only | NR | | Median: 62 years | 51% | 815
CancerTypeID Thompson, 2011^12^ 2008–2011 U.S. only | NR | | NR | NR | Total N: 171 CRC patients (data for KQ 4b): 21 | CUP with colorectal TOO result
CancerTypeID Weiss, 2012^13^ NR U.S. | NR | | Mean (SD): 61.2 (14.4) years | 52% | 123 | Metastatic
CancerTypeID Wu, 2012^14^ NR China | Chinese | | NR | 94 | 184 | Adrenal, breast, endometrium, gall bladder, gastroesophageal germ cell, GIST, head and neck, intestine, kidney, liver, lung, lymphoma, melanoma, mesothelioma, neuroendocrine, ovary, pancreas, prostate, sarcoma, skin, thyroid, urinary/bladder
G-banded karyotype (supplemented by FISH and comparative genomic hybridization Pantou 2003^15^ 2001 Multinational, not U.S. | NR | Multiple age groups | < 25 (1) 25–50 (4) 50–64 (4) 65-older (7) Mean age: 59.2 | 3 | 34 | CUP
miRview mets^2^ Meiri 2012^17^ 1990–2010 NR | NR | NR | NR | NR | 509 Interlaboratory correlation: 179 | Adrenal, anus, biliary tract, bladder, brain, breast, cervix, colon/rectum, gastrointestinal, liver, lung, head and neck, esophagus, lymphoma, mesothelioma, ovary, pancreas, prostate, sarcoma, skin, testis, thymus, thyroid
miRview Mueller 2011^18^ 2008 Germany | NR | NR | NR | NR | 102 | Billary tract, breast, head and neck, kidney, liver, lung, melanocyte, ovary, stomach or esophagus, thyroid, colon
miRview Pavlidis 2012^19^ NR NR Good | NR | NR | NR | NR | 92 | CUP
miRview Rosenfeld 2008^20^ NS Multinational, not U.S. | NR | NR | NR | NR | 80 | Bladder, brain, breast, colon, endometrium, head & neck, kidney, liver, lung, lung pleura, lymph node, melanocytes, meninges, ovary, pancreas, prostate, sarcoma, stomach, gist, testis, thymus, thyroid
miRview Rosenwald 2010^21^ NS Multinational, U.S. | NR | NR | NR | NR | 649 Learning set. 204 Validation | Biliary tract, brain, breast, colon, esophagus, head and neck, kidney, liver, lung, melanoma, ovary, pancreas, prostate, stomach or esophagus, testis, thymus, thyroid
miRview Varadhachary 2011^22^ 2008–2010 U.S. only | NR | NR | Median: 58 Range: 20–83 | Total: 66 Results: 45 | 104 | lymph nodes, liver, lung, bone, pelvic mass/adnexae, skin/subcutaneous, omentum/peritoneum, adrenal, other
Pathwork Tissue of Origin Test Azueta, 2012^23^ 1992–2010 Spain | NR | | NR | NR | 32 | Ovarian, peritoneal carcinomatosis
PathworkDx Beck 2011^24^ NS U.S. only | NR | NR | NR | NR | 49 | Bladder, breast, colorectal, gastric, hepatocellular, melanoma, liver, synovial sarcoma, sarcoma, ovarian, pancreatic, prostate, renal, thyroid
PathworkDx Dumar 2008^25^ NS U.S. only | NR | NR | NR | NR | 60 | Breast, colorectal, nonsmall-cell lung, non-Hodgkin’s lymphoma, lymphoma, pancreas, bladder, gastric, germ cell, hepatocellular, kidney, melanoma, ovarian, prostrate, soft tissue, sarcoma, thyroid
PathworkDx Grenert 2011^26^ 2000–2007 U.S. only | NR | Multiple age groups | Median: 55 Range: 22–74 | 20 | 45 | Bladder, breast, colorectal, gastric, testicular gem cell, kidney, hepatocellular, nonsmall cell lung, non-Hodgkin’s lymphoma, melanoma, ovarian, pancreas, prostate, sarcoma, thyroid
PathworkDx Hainsworth, 2011^27^ 2005 U.S. only | NR | Multiple age groups | Range: 21–86 Median: 56 | 21 | 48 | CUP
PathworkDx Hornberger, 2012^28^ NR NR | Race: White: 95 African American: 4 Hispanic: 4 Asian American: 2 Other: 2 N | | Patients: Mean: 64 (SD:12) | 61 | Patients: 107 | Any
Pathwork Tissue of Origin Test Kulkarni, 2012^29^ 2007–2011 U.S. only | NR | | NR | 3 | 10 | Metastatic tumors from clinically identified primary site not diagnosed by IHC alone
Pathwork Tissue of Origin Endometrial Test Lal, 2012 30 NR U.S. only | NR | | 30–50: 9 50–60: 24 60–70: 28 70–90: 14 | 75 | 75 | Ovarian, endometrial
Pathwork Tissue of Origin Test Laouri, 2011^31^ 2009 U.S. only | NR | | Median: 62 years Range: 16–69 years | 161 57% | 284 | Liver, lymph node, omentum and peritoneum, lung, soft tissue, bone, neck, brain, ovary, colon and rectum, pleura, pelvis, small bowel, other
PathworkDx Monzon 2010^32^ 2006 U.S. only | NR | Multiple age groups | 40–49: 1 50–59: 4 60–69: 6 70–79: 7 80–89: 3 | 15 | 21 | CUP
PathworkDx Monzon 2009^33^ NS Multinational, U.S. | NR | Multiple age groups | < 50 (142 50–59 (133) 60–69 (139) >= 70 (132) | 290 | 547 | Colorectal, pancreatic, nonsmall cell lung, breast, gastric, kidney, hepatocellular, ovary, sarcoma, non-Hodgkin’s lymphoma, thyroid, prostate, melanoma, bladder, testicular germ cell
PathworkDx Nystrom 2012^34^ NR U.S. only | Race: White: 95 African American: 4 Hispanic: 4 Asian American: 2 Other: 2 | | Mean (SD): 64 (12) | 61 | Physician: Ordered TOO test N: 65 (of 308 eligible) N: 107 patients N: 316 physicians | Lymph node, soft tissue, liver, lung, bone, brain CUP
PathworkDx Pillai 2011^35^ NS U.S. only | NR | Multiple age groups | 10–20: 1 20–30: 19 30–40: 44 40–50: 79 50–60: 133 60–70: 104 70–80: 63 ≥ 80: 14 | 257 | 462 | Bladder, breast, colorectal, gastric, testicular germ cell, kidney, hepatocellular, and nonsmall cell lung cancer, as well as non-Hodgkin’s lymphoma, melanoma, ovarian cancer, pancreatic cancer, prostate cancer, thyroid cancer, and sarcoma.
Pathwork Tissue of Origin Test Pollen, 2011^36^ | NR | | NR | NR | 19 | NR
PathworkDx Stancel 2011^37^ NS U.S. only | NR | | NR | NR | 27 | Lung, lymphoma, colon, pancreas, breast, ovarian, gastric
PathworkDx Wu 2010^38^ NS U.S. only | NR | Multiple age groups | Range: 21–56 Median: 41 | 3 | 15 | Lung, breast, melanoma, lymphoma, sarcoma, colon, head and neck, gastric, kidney

Abbreviations: CUP = cancer of unknown primary; GIST = gastrointestinal stromal tumor; MFH = malignant fibrous histiocytoma; N= number; NR = not reported; NS = not significant; SD = standard deviation; U.S. = United States.

Table C-2 KQ 2. Evidence of analytic validity of tissue-of-origin tests

Tissue of Origin Test, Author, Year | Range of Sensitivity and Specificity for Measuring the Markers | Number of Outliers, Cross Reaction of Markers With Normal Tissue | Antibodies Monoclonal, Robustness of Antibodies | QC Measures for Markers | Required % of Valid Markers | QC Standards for Assay | Changes in Panel Precision and Accuracy Over Time
CancerTypeID Erlander, Ma 2011^1^ | Sensitivity NR Specificity NR | NR NR | NR NR | Assay reproducibility (expressed as mean percentage coefficient of variation): Ct values using positive controls (194 independent runs, 4 operators): 92 assay genes- 1.69%; 5 normalization genes −2.19%. Ct values using negative controls (194 independent runs, 4 operators): 92 assay genes-1.25%; 5 normalization genes −1.66%. Assays of known tumor types (32 assays, 3 tumor types, 4 scientists): The mean percentage CVs were 1.58% (range 1.41%–1.69%) for the 92 genes and 1.04% (range, 0.85% to 1.79%) for the 5 normalization genes. 100% concordance for tumor of origin prediction. Across tumor type (6 tumor types, 3 setups, 2 operators): 92 assay genes - 3.33%; 5 normalization genes - 3.16%. | NR | NR | NR
miRview mets^2^ Meiri 2012^17^ | Range of accuracy: NR Range of specificity: NR | Number of outliers: NR Cross-reaction with normal tissue: NR | NR | Positive control QA measures: Number of miRNAs with expression >300 (dynamic range); 98th percentile expression level of the miRNA Pearson correlation between sample and reference hybridization spikes Number of miRNAs with consistent triplicate signals Mean correlations coefficient of multiple assays of same sample: 0.99 | NR | NR | Interlaboratory correlation: >0.95 in 89% of samples. Interlaboratory agreement on diagnosis: 175/179 (98%)
miRview Rosenfeld 2008^20^ | Sensitivity NR Specificity NR | NR NR | NR NR | NR | NR | Array platform validated by RT-PCR. miRNAs maintained expression distributions and diagnostic roles. | NR
miRview Rosenfeld 2010^21^ | Sensitivity NR Specificity NR | NR NR | NR NR | Number and identity of microRNAs (C<38) and average Ct of measured microRNAs. microRNA results consistent across 3 platforms (spotted arrays, custom commercial arrays, and qRT-PCR). Between-lab correlation of qRT-PCR signals per sample=0.98. Labs disagreed on 3 samples; 8 agreed on one answer; 61 matched perfectly. N=72 | NR | NR. | Negative control: no RNA sample. Positive control: specific RNA sample that should meet defined range in assay QA based on fluorescence amplification
miRview Varadhachary 2011^22^ | Sensitivity NR Specificity NR | NR NR | NR NR | NR | 87/104 samples passed tumor content criteria. 74/87 passed all QA criteria. | Controls: No sample; no RNA; external positives. Quality parameters for RNA amplification. | NR
PathworkDx Dumar 2008^25^ | Sensitivity Pre-standardization 1- to-1 lab correlation: Pearson correlation coefficients 0.65–0.82 Post standardization 1- to-1 lab correlation: 0.81 to 0.87 Coefficient of reproducibility: 32.48 +/− 3.97 Specificity NR | 19/227 NR | NR NR | All samples with adequate RNA quantity and quality produced sufficient cRNA for hybridization. 31/227 samples required >1 labeling reaction. Data verification algorithm addresses RNA quality, inadequate amplification, insufficient quantity of labeled RNA, inadequate hybridization time or temperature. 218/227 gene expression data files passed verification. All 9 failed files showed evidence of RNA degradation. | NR | No evidence of bias. Similarity Score interlaboratory correlation: 0.95. Concordance of Physician Guided Conclusion: 89.4% (range, 87.0 – 92.5). Kappa > 0.86. | NR
PathworkDx Dumur, 2011^39^ | Range of accuracy: NR Range of specificity: NR | Number of outliers: NR Cross-reaction with normal tissue: NR | | NR | NR | NR | Required percentage of valid markers: ≥40 Percentage of present probes: Mean: 60.6 Range: 49.9–69.3% QC standards for assay: 3´/5´ ratio for glyceraldehyde-3-phosphate dehydrogenase ≤3.0* Mean 3´/5´ GAPDH ratio: 1.2 Range: 0.9–3.0 PathworkDX TOO test report: “Acceptable” data quality
Pathwork Tissue of Origin Endometrial Test Lal, 2012^30^ | NR | NR | NR | NR | NR | NR | Intrasite reproducibility=46/46 Concordance percentage: 100% (95% CI: 92.3–100) Intersite reproducibility=83/88 Concordance percentage: 94.3% (95% CI: 87.2–98.1) Median coefficient of variation (CV%) of the similarity score: 1.38 (range 0.32–8.79) Kappa (Κ) statistic: 1.0 for all three pairwise comparisons. Changes in panel precision and accuracy over time: Test performance 90.5% for specimens >2 years old

Abbreviations: CI = confidence interval; Ct = cycle threshold; CV = coefficient of variation; GAPDH = glyceraldehyde-3-phosphate dehydrogenase; microRNA = micro ribonucleic acid; miRNA = micro ribonucleic acid; NR = not reported; QA = quality assurance; qRT-PCR = quantitative reverse transcriptase polymerase chain reaction; RNA = ribonucleic acid; RT-PCR = reverse-transcriptase polymerase chain reaction; TOO = tissue of origin.

Table C-3 KQ 3a. Evidence of accuracy of tissue-of-origin tests in classifying the origin and type of tumor and adherence of statistical methods to guidelines40

Tissue of Origin Test, Author, Year | Total Expression | Selected Housekeeping | Hypothesis Tests | Ranking | Clustering (e.g., PCA) | Classification | Internal | External
CancerTypeID Ma, 2006^9^ | NR | Raw Cy5/Cy3 ratios per array were normalized using nonlinear local regression, without background adjustment | Logistic regression | NR | NR | Supervised Logistic Regression | Leave-one-out cross-validation to select genes; Multiclass weighted K-Nearest Neighbor Classification algorithm to classify genes; Gene selection also done via Genetic algorithm | Validation study of 187 FFPE tumor samples
miRview Rosenfeld 2008^20^ | Based on median expression level for each probe across all samples | NR | NR | NR | NR | Unsupervised KNN algorithm Supervised Logistic regression decision-tree algorithm | Leave one-out cross validation within the training set | Blinded test set with independent set of 83 samples
miRview Rosenwald 2010^21^ | Average expression of all microRNAs of the sample + scaling constant (the average expression over the entire sample set) | NR | NR | Decision tree algorithm used that finally selected 48 miRNAs through feature selection | NR | Supervised: Binary decision tree KNN | Leave-one-out cross validation within the training set | Test performance assessed using independent set of 204 validation samples

Abbreviations: FFPE = formalin-fixed paraffin-embedded; K = Kappa; KNN = K-nearest neighbor; microRNAs = micro ribonucleic acid; NR = not reported.

Table C-4 KQ 3b–f. Evidence of accuracy of the tissue-of-origin test in classifying the origin and type of the tumor: Accuracy of CUP compared to gold standard

Tissue of Origin Test, Author, Year | Sample Size | Gold Standard (Comparison Test) | Sensitivity | Specificity
CancerTypeID Erlander, Ma 2011^1^ | 187 | Known origin | 0.83 (numbers not reported) | 0.99
CancerTypeID Kerr, 2012^8^ U.S.CAP abstract | 75 | Clinicopathological diagnosis | 71/75 (95%) | NR
CancerTypeID Kerr, Schnabel 2012^7^ Clinical Cancer Research | 790 | Diagnosis adjudicated prior to blind TOO testing | Overall Sensitivity = 87% (95% confidence interval (CI), 84 to 89) | Incorrect exclusion 5% cases
CancerTypeID Ma, Patel, et al., 2006^9^ | Validation: 119 FFPE | Known origin | "Accuracy" Overall (95% CI): 82% (74% to 89%) Unclassifiable - 8 (6.7%) | NR
CancerTypeID Weiss et al., 2012^13^ | N=123 | Final clinicopathological diagnosis | Accuracy: IHC=0.68 CTID=0.78 p=0.017 | NR
CancerTypeID Wu F, 2012^14^ | N=184 | Clinicopathological diagnosis | 151/184 (82.1%) | NR
miRview mets^2^ Meiri 2012^17^ | 509 | Known origin | One of two predictions accurate: 418/489 Single prediction made: 361/403 accurate | > 99%
miRview Mueller 2011^18^ | 89 [excludes 12 cases of prostate cancer] | Known origin | 75/89 for at least one classifier For 52 with single prediction: 46/52 | 95% Among 52 with single prediction: 99%
miRview Rosenfeld 2008^20^ | 83 (blinded test set) | Known origin | Combined accuracy using Decision Tree & KNN = 86% | Combined value not available Decision Tree=99% KNN=NR
miRview Rosenwald 2010^21^ | 204 validation samples; 7 metastases from patients whose primary tumor was previously profiled. 188 passed QA | Known origin | 84.6% Single prediction: 89.5% | 96.9 Single predictions: 99.3%
PathworkDx Beck 2011^24^ | 42 (39 on panel) | known origin | 29/39 Indeterminate: 7/39 Incorrect: 3/39 | NR
PathworkDx Dumur 2008^25^ | 60 | Known origin | All samples (range): 86.7% (84.9–89.3%) Samples within manufacturer’s tissue quality control parameters: Average (range): 93.8 (93.3–95.5%) Indeterminate: 5.5% to 11.3% | NR
PathworkDx Dumur 2011^39^ | 43 | Clinicopathologic diagnosis | Agreed: Known on-panel: 97 (28/29) 95% CI (80.4–99.8) | NR
Pathwork Grenert 2011^26^ | 37 | 95% (81.8 – 99.3) | 99.60% | NR
Pathwork Tissue of Origin Test Kulkarni, 2012^29^ | N=10 | Final clinicopathological diagnosis | Correct diagnosis: TOO: 9/10 (90%) Overall pathologist (5) review of IHC (10 cases): 32 /50 (64%) Individual pathologists: range 5/10 to 8/10 | NR
Pathwork Tissue of Origin Endometrial Test Lal 2012 30 | 75 | Clinical diagnosis | 71/75 (94.7) (86.9–98.5) AUC: 0.997 | NR
PathworkDx Monzon 2009^33^ | 547 | Known origin | 480/547 (87.8%) (84.7–90.4) | 99.40%
PathworkDx Pillai 2010^35^ | 462 | Known origin | Overall agreement: 409/462. Sensitivity: 88.5 | 99.1
PathworkDx Stancel 2011^37^ | 20 Passed QA: 19 | Known origin | 15/19 (78.9%) | NR
PathworkDx Wu 2010^38^ | 15 Results, 1 off-panel specimen: 14 Sample size = 13 | Known origin | 12/13(92%) | NR

Abbreviations: AUC = area under receiver operating curve; CI = confidence interval; FFPE = formalin-fixed paraffin-embedded; IHC = immunohistochemistry; KNN = K-nearest neighbor; N= number; QA = quality assurance; TOO = tissue of origin.

Table C-5 KQ 3b–f. Evidence of accuracy of the tissue-of-origin test in classifying the origin and type of the tumor: Site-specific accuracy of CUP

Tissue of Origin Test, Author, Year | Sample size | Gold Standard (Comparison Test) | Site | Sample Size | Sensitivity | Specificity
CancerTypeID Erlander, 2011^1^ | 187 | Known origin | 1. Adrenal 2. Brain 3. Breast 4. Cholangio-carcinoma 5. Endometrium 6. Gallbladder 7. Gastroesophageal 8. Germ cell 9. GIST 10. Head/neck 11. Intestine 12. Kidney 13. Liver 14. Lung 15. Lymphoma 16. Melanoma 17. Meningioma 18. Mesothelioma 19. Neuroendocrine 20. Ovary 21. Pancreas 22. Prostate 23. Sarcoma 24. Sex cord stromal tumor 25. Skin 26. Thymus 27. Thyroid 28. Urinary bladder | 1. 2 2. 5 3. 11 4. 7 5. 4 6. 6 7. 14 8. 6 9. 1 10. 13 11. 16 12. 5 13. 7 14. 13 15. 10 16. 5 17. 1 18. 2 19. 7 20. 6 21. 8 22. 8 23. 6 24. 1 25. 9 26. 2 27. 5 28. 7 | 1. 1.00 2. 1.00 3. 1.00 4. 0.71 5. 0.75 6. 0.67 7. 0.86 8. 1.00 9. 1.00 10. 0.54 11. 0.63 12. 1.00 13. 1.00 14. 0.92 15. 1.00 16. 0.80 17. 1.00 18. 1.00 19. 1.00 20. 0.83 21. 0.63 22. 0.88 23. 1.00 24. 1.00 25. 0.67 26. 0.50 27. 1.00 28. 0.86 | 1. 1.00 2. 1.00 3. 1.00 4. 0.99 5. 0.99 6. 0.98 7. 0.97 8. 0.98 9. 1.00 10. 0.99 11. 1.00 12. 1.00 13. 1.00 14. 0.98 15. 0.99 16. 1.00 17. 1.00 18. 0.99 19. 1.00 20. 0.99 21. 0.99 22. 1.00 23. 0.99 24. 1.00 25. 0.99 26. 1.00 27. 1.00 28. 0.99
CancerTypeID Kerr, 2012^8^ USCAP abstract | 75 | Clinicopathological diagnosis | 1. Intestinal 2. Lung high grade 3.Lung low grade 4. Merkel cell 5. Pancreas 6. Pheo/paraganglioma 7. Thyroid medullary | 1. 12 2. 11 3. 11 4. 10 5. 10 6. 10 7. 11 | 1. 12/12 (1.00) 2. 10/11 (0.91) 3. 10/11 (0.91) 4. 10/10 (1.00) 5. 8/10 (0.80) 6. 10/10 (1.00) 7. 11/11 (1.00) | 1. 1.00 2. 1.00 3. 1.00 4. 0.97 5. 0.98 6. 1.00 7. 1.00
CancerTypeID Kerr, Schnabel 2012^7^ Clinical Cancer Research | 790 | Diagnosis adjudicated prior to blind TOO testing | Adrenal Brain Breast Cervix adenocarcinoma Endometrium Gastroesophageal Germ cell GIST Head-neck-salivary Intestine Kidney Liver Lung-adeno/large cell Lymphoma Melanoma Meningioma Mesothelioma Neuroendocrine Ovary Pancreaticobiliary Prostate Sarcoma Sex cord stromal tumor Skin basal cell Squamous Thymus Thyroid Urinary bladder | 25 25 25 25 25 25 25 25 25 25 30 25 25 25 25 25 25 50 40 30 25 60 25 25 30 25 25 25 | 0.96 (0.80–1.00) 0.96 (0.80–1.00) 0.80 (0.56–0.94) 0.72 (0.47–0.90) 0.48 (0.26–0.70) 0.65 (0.41–0.85) 0.83 (0.61–0.95) 0.92 (0.74–0.99) 0.88 (0.68–0.97) 0.85 (0.62–0.97) 0.97 (0.83–1.00) 0.96 (0.80–1.00) 0.65 (0.43–0.84) 0.84 (0.64–0.95) 0.88 (0.69–0.97) 1.00 (0.80–1.00) 0.87 (0.66–0.97) 0.98 (0.89–1.00) 0.86 (0.71–0.95) 0.88 (0.68–0.97) 1.00 (0.80–1.00) 0.95 (0.86–0.99) 0.80 (0.59–0.93) 1.00 (0.80–1.00) 0.86 (0.68–0.96) 0.72 (0.51–0.88) 0.96 (0.80–1.00) 0.64 (0.41–0.83) | 0.99 (0.98–1.00) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 0.99 (0.99–1.00) 1.00 (0.99–1.00) 0.99 (0.99–1.00) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 0.99 (0.98–1.00) 0.98 (0.97–0.99) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 0.98 (0.97–0.99) 0.99 (0.98–1.00) 1.00 (0.99–1.00) 0.99 (0.97–0.99) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 0.98 (0.97–0.99) 1.00 (0.99–1.00) 1.00 (0.99–1.00) 0.99 (0.98–1.00)
CancerTypeID Ma, 2006^9^ | Validation: 119 FFPE | Known origin | 1.Adrenal 2. Brain 3. Breast 4. Carcinoid–intestine 5. Cervix–adeno 6. Cervix–squamous 7. Endometrium 8. Gallbladder 9. Germ–cell 10. GIST 11. Kidney 12. Leiomyosarcoma 13. Liver 14. Lung–adeno–large cell 15. Lung–small 16. Lung–squamous 17. Lymphoma 18. Meningioma 19. Mesothelioma 20. Osteosarcoma 21. Ovary 22. Pancreas 23. Prostate 24. Skin–basal cell 25. Skin–melanoma 26. Skin–squamous 27. Small and large bowel 28. Soft-tissue 29. Stomach–adeno 30.Thyroid–follicular–papillary 31.Thyroid–medullary 32.Urinary bladder 33. Overall | 1. 1 2. 3 3. 1 4. 2 5. 2 6. 3 7. 3 8. 0 9. 9 10. 3 11. 4 12. 3 13. 2 14. 3 15. 5 16. 3 17. 10 18. 3 19. 5 20. 2 21. 5 22. 3 23. 7 24. 4 25. 4 26. 3 27. 6 28. 8 29. 3 30. 3 31. 0 32. 6 33. 481 | FFPE Accuracy 1. 1.00 2. 1.00 3. 1.00 4. 1.00 5. 0.50 6. 0.67 7. 0.67 8. - 9. 0.78 10. 1.00 11. 1.00 12. 0.33 13. 1.00 14. 0.00 15. 0.40 16. 1.00 17. 1.00 18. 1.00 19. 0.80 20. 1.00 21. 1.00 22. 1.00 23. 1.00 24. 0.75 25. 0.75 26. 1.00 27. 0.83 28. 0.88 29. 0.00 30. 1.00 31. - 32. 1.00 33.119 | NR
CancerTypeID Weiss et al., 2012^13^ | N=123 | Final clinicopathological diagnosis | 1. Lung 2. Urinary/bladder 3. Breast 4. GI 5. Kidney | NS | 1. CTID=75, IHC=67 2. CTID=75, IHC=42 3. CTID=73, IHC=55 4. CTID=77, IHC=77 5. CTID=77, IHC=77 | NR
CancerTypeID Wu F, 2012^14^ | N=184 | Clinicopathological diagnosis | 1. Adrenal 2. Breast 3. GIST 4. Intestine 5. Liver 6. Lymphoma 7. Prostate 8. Thyroid 9. Germ-cell 10. Neuroendocrine 11. Kidney 12. Lung 13. Skin 14. Gallbladder 15. Melanoma 16. Urinary Bladder 17. Sarcoma 18. Pancreas 19. Head & Neck 20. Ovary 21. Gastroesophageal 22. Mesothelioma 23. Endometrium | 1. 2 2. 10 3. 6 4. 8 5. 6 6. 5 7. 7 8. 10 9. 10 10. 9 11. 8 12. 8 13. 6 14. 5 15. 5 16. 10 17. 13 18. 7 19. 10 20. 14 21. 12 22. 7 23. 6 | 1. 1.000 2. 1.000 3. 1.000 4. 1.000 5. 1.000 6. 1.000 7. 1.000 8. 1.000 9. 1.000 10. 0.889 11. 0.875 12. 0.875 13. 0.833 14. 0.800 15. 0.800 16. 0.800 17. 0.769 18. 0.714 19. 0.700 20. 0.643 21. 0.583 22. 0.571 23. 0.333 | 1. 0.995 2. 0.994 3. 1.000 4. 0.994 5. 1.000 6. 0.994 7. 1.000 8. 1.000 9. 1.000 10. 0.983 11. 0.989 12. 0.983 13. 0.994 14. 0.983 15. 0.994 16. 0.971 17. 1.000 18. 0.994 19. 1.000 20. 0.976 21. 0.988 22. 1.000 23. 0.994
miRview Mueller 2011^18^ | 89 [excludes 12 cases of prostate cancer] | Known origin | 89 (Samples with known TOO) | 1. 0% 2. 72.2% 3. 100% 4. 94.12% 5. 100% 6. 87.5% 7. 100% 8. 60% 9. 100% 10. 0% 11. 75% Prostate: 9 of 12 incorrectly classified | 1. 100% 2. 95.8% 3. 89.4% 4. 98.6% 5. 100% 6. 78.1% 7. 90.3% 8. 97.6% 9. 98.8% 10. 97.7% 11. 95.3% Overall 95% | NR
miRview Rosenfeld 2008^20^ | 83 (blinded test set) | Known origin | 1. Bladder 2. Brain 3. Breast 4. Colon 5. Endometrium 6. Head & neck 7. Kidney 8. Liver 9. Lung 10. Lung pleura 11. Lymph node 12. Melanocytes 13. Meninges 14. Ovary 15. Pancreas 16. Prostate 17. Sarcoma 18. Stomach 19. Stromal 20. Testis 21. Thymus 22. Thyroid | 1. 2 2. 5 3. 5 4. 5 5. 3 6. 8 7. 5 8. 2 9. 5 10. 2 11. 5 12. 5 13. 3 14. 4 15. 2 16. 2 17. 5 18. 7 19. 2 20. 1 21. 2 22. 3 | Decision Tree 1. 0 2. 100 3. 60 4. 40 5. 0 6. 100 7. 100 8. 100 9. 80 10. 50 11. 60 12. 60 13. 100 14. 75 15. 50 16. 100 17. 40 18. 71 19. 100 20. 100 21. 100 22. 100 | Decision Tree 1. 100 2. 100 3. 97 4.99 5.99 6.99 7.99 8.99 9.95 10. 99 11. 100 12. 97 13. 99 14. 97 15. 100 16. 100 17. 99 18. 96 19. 100 20. 100 21. 98 22. 100
miRview Rosenwald 2010^21^ | 204 validation samples; 7 metastases from patients whose primary tumor was previously profiled. 188 passed QA | Known origin | Validation 1. Biliary tract 2. Brain 3. Breast 4. Colon 5. Esophagus 6. Head and neck 7. Kidney 8. Liver 9. Lung 10. Melanoma 11. Ovary 12. Pancreas 13. Prostate 14. Stomach or esophagus 15. Testis 16. Thymus 17. Thyroid | Validation only 1. 7 2. 11 3. 38 4. 9 5. 1 6. 3 7. 10 8. 8 9. 26 10. 7 11. 13 12. 6 13. 20 14. 7 15. 8 16. 6 17. 24 | (1 or 2 predictions) 1. 66.7% 2. 100% 3. 66.7% 4. 88.9% 5. 100% 6. 100 7. 87.5% 8. 100% 9. 91.3% 10. 85.7% 11. 84.6% 12. 50% 13. 89.5% 14. 40% 15. 100% 16. 83.3% 17. 100% | (1 or 2 predictions) 1. 94% 2. 100% 3. 93.6% 4. 94.4% 5. 98.4% 6. 92.4% 7. 99.4% 8. 99.4% 9. 84.9% 10. 97.8% 11. 100% 12. 97.8% 13. 99.4% 14. 98.9% 15. 100% 16. 97.8% 17. 98.2%
PathworkDx Beck 2011^24^ | 42 (39 on panel) | Known origin | NR | NR | 1. 100% 2. 0% 3. 0% | 1. 100% 2. 0% 3. 0%
PathworkDx Grenert, Smith 2011^26^ | 37 | 95% (81.8 - 99.3) | 1. Bladder 3 2. Breast 2 3. Colorectal 3 4. Gastric 2 5.Testicular gem cell 3 6. Kidney 4 7. Hepatocellular 3 8. Nonsmall cell lung 2 9. Non-Hodgkin’s lymphoma 3 10. Melanoma 2 11. Ovarian 3 12. Pancreas 2 13. Prostate 1 14 Sarcoma 3 15 Thyroid 1 | 1. 3 2. 2 3. 3 4. 2 5. 3 6. 4 7. 3 8. 2 9. 3 10. 2 11. 3 12. 2 13. 1 14. 3 15. 1 | 1. 3 2. 2 3. 3 4. 2 5. 2 6. 4 7. 3 8. 2 9. 3 10. 2 11. 2 12. 2 13. 1 14. 3 15. 1 | NR
Pathwork Tissue of Origin Endometrial Test Lal, 2012^30^ | 75 | Clinical diagnosis | 1. Ovarian 2. Endometrial | 1. 30 2. 45 | 1. 42/45; 0.967 (0.817–0.986) 2. 29/30; 0.933 (0.828–0.999)
PathworkDx Monzon 2009^33^ | 547 | Known origin | 1. Bladder 2. Breast 3. Colorectal 4. Gastric 5. Germ Cell 6. Hepatocellular 7. Kidney 8. Melanoma 9. Non-Hodgkin’s lymphoma 10. Non–small cell lung 11. Ovarian 12. Pancreas 13. Prostate 14. Soft tissue sarcoma 15. Thyroid | 1. 28 2. 68 3. 56 4. 25 5. 30 6. 25 7. 39 8. 26 9. 33 10. 31 11. 69 12. 25 13. 26 14. 31 15. 35 | 1. 22/28 2. 64/68 3. 52/56 4. 18/25 5. 22/30 6. 23/25 7. 37/39 8. 21/26 9. 31/33 10. 27/31 11. 64/69 12. 18/25 13. 23/26 14. 26/31 15. 32/35 | 1. 519/519 2. 471/479 3. 487/491 4. 519/522 5. 517/517 6. 521/522 7. 507/508 8. 520/521 9. 511/514 10. 509/516 11. 473/478 12. 521/522 13. 521/521 14. 513/516 15. 510/512
PathworkDx Pillai 2011^35^ | 462 | Known origin | 1. Bladder 2. Breast 3. Colorectal 4. Gastric 5. Hepatocellular 6. Kidney 7. Melanoma 8. Non-Hodgkin’s lymphoma 9. Nonsmall cell lung 10 Ovarian 11 Pancreas 12 Prostate 13. Sarcoma 14. Testicular germ cell 15. Thyroid | 1. 29 2. 57 3. 36 4. 25 5. 25 6. 28 7. 25 8. 29 9. 27 10. 45 11. 28 12. 25 13. 27 14. 25 15. 31 | 1. 23/29 2. 55/57 3. 33/36 4. 18/25 5. 24/25 6. 25/28 7. 21/25 8. 26/29 9. 23/27 10. 40/45 11. 24/28 12. 24/25 13. 24/27 14. 21/25 15. 28/31 | NR
PathworkDx Stancel 2011^37^ | 20 Passed QA: 19 | Known origin | 1. Lung (4) 2. Lymphoma (2) 3. Colon (1) 4. Pancreas (1) 5. Breast (4) 6. Ovarian (5) 7. Gastric (2) | | Agreement: 1. 3/4 2. 2/2 3. 0/1 4. 1/1 5. 3/4 6. 5/5 7. 1/2 | NR
PathworkDx Wu 2010^38^ | 15 Results, 1 off-panel specimen: 14 Sample size = 13 | Known origin | 1. Lung 2. Breast 3. Melanoma 4. Lymphoma 5. Sarcoma 6. Colon 7. Head & Neck (off-panel) 8. Gastric | 1. 3 2. 3 3. 2 4. 3 5. 1 6. 1 7. 1 8. 1 | Accuracy of test: 1. 1/3 2. 3/3 3. 2/2 4. 3/3 5. 1/1 6. 1/1 7. 0/1 8. 1/1 | NR

Abbreviations: FFPE = formalin-fixed paraffin-embedded; GIST = gastrointestinal stromal tumor; IHC = immunohistochemistry; N= number; NR = not reported; QA = quality assurance; TOO = tissue of origin; USCAP = United States and Canadian Academy of Pathology.

Table C-6 KQ 4. Evidence of ability of tissue of origin tests to identify the primary tumor site in CUP cases

Tissue of Origin Test | First Author, Publish Year | TOO Predicted Result (Confirmed) | Indeterminate Results | # Cases Clinically Useful
CancerTypeID | Erlander, Ma 2011^1^ | 296 (142) | 4 | 252
CancerTypeID | Greco 2010^2^ | 18 (15) | 2 | NR
CancerTypeID | Schroeder11 | 91% | | Pretest diagnosis unknown: CTID diagnosed 59 (93%) cases Differential diagnosis provided: CTID resolved dx in 55% cases. Provided new primary dx: 36%
CancerTypeID | Thompson12 | CTID=144 (By latent primary: 18/24 (75%); by IHC or clinical features: 101/144 (70%)) | 5 | Confirmed 1 of 2-3 IHC diagnoses: 43/97
G-banded karyotype (supplemented by FISH and comparative genomic hybridization | Pantou 2003^15^ | 5/20 identified cases 2/20 no mitoses 1/20 normal karyotype | NR | NR
miRview | Mueller 2011^18^ | 50 (40) 10 were discordant 4 origin never diagnosed | NR | NR
miRview | Pavlidid 2012^19^ | 84/92 (92%) | 8 | NR
miRview | Varadhachary 2011^22^ | 74 (62) | NR | IHC not helpful: 9 TOO prediction: 9 TOO consistent with clinicopathological: 7
Pathwork | Azueta 2012^23^ | Total: TOO: 32 (25/29) IHC: 28 (20/29) Peritoneal: TOO: 7 (7) IHC: 5 (5) Ovarian: TOO: 18 (22) IHC: 15 (22) Unknown: TOO: 2 IHC: 2 | NR | NR
Pathwork | Beck 2011^24^ | 4 (2 clearly incorrect) | 3 | 2
Pathwork | Dumur 2011^39^ | Overall: 29/40 (28); On panel: 28/29; Off panel: 4 discordant, 9 unreported | 3 inadequate sample: 1 indeterminate, 2 discordant. Off panel: 2 indeterminate | 29/40. Confirmed original diagnosis: 23 Changed diagnosis: 5 Excluded suspected diagnosis: 1 TOO results obtained “several months” before IHC and imaging results.
Pathwork | Hainsworth 2011^27^ | 43 | 2 | NR
Pathwork | Laouri, 2011^31^ | Non-specific dx: 172 Specific Dx: 100 (New 57; Confirm 43) | No Specific Dx: 11 Specific Dx: 1 | NR
Pathwork | Monzon 2010^32^ | 16 (10) 6 plausible | 5 | 16
Pathwork | Nystrom 2012^34^ | NR | NR | Changed diagnosis: 54/107 Provide diagnosis for patients with no working diagnosis: 27/44 No change in tissue site diagnosis: 37/107 Physician found test clinically useful: 66%

Abbreviations: Dx/dx = diagnosis; FISH = fluorescent in situ hybridization; IHC = immunohistochemistry; NR = not reported; TOO = tissue of origin

Table C-7 KQ 4a. Evidence of genetic tissue-of-origin tests changed treatment decisions

Tissue of Origin Test, Author, Year | # Eligible | Response | Sample Requirements | Identity Score | Indicated TOO | Treatment | Treatment Response | TOO Did NOT Change Treatment | TOO Changed Treatment | P-value TOO vs. CUP
CancerTypeID Greco 2012^3^ | 32 | 32 | Colorectal gene expression signature | | Colorectal cancer | First-line: Folfox/Folfiri 19 Other colorectal cancer drug: 4 Empiric: 8 (6/8 received CRC treatment for second-line) First-line CRC treatment: 17/23 (74%) Second-line CRC: 7/13 (54%) Any first-line treatment: 22/32 (69%) Any secondline treatment 7/13 (54%) | | Not applicable: retrospective study | Not applicable: retrospective study
CancerTypeID Hainsworth 2010^5^ | 110 | Received assay directed treatment: 66 Evaluated: 51 | Not a treatable C-subset of CUP No previous systematic treatment ECOG performance status 0–2 No uncontrolled brain metastases | NS | Pancreatic: 11 Colorectal: 8 Urinary Bladder: 8 Nonsmall cell lung: 5 Ovarian: 4 Carcinoid - interstine: 4 Breast: 3 Gallbladder: 3 Liver: 3 Renal cell: 3 Skin (squamous): 3 Other: 7 No specific diagnosis: 5 | Assay directed treatment | Objective treatment response: 21 | 44 (40%) | 66 (60%) | 51% response for assay directed therapy
CancerTypeID Hainsworth, 2011^4^ | 125 | 42 (34%) | NS | NS | Identified by TOO test with ≥ 80% probability as colorectal adenocarcinoma | 1. 1st line: Advanced colorectal cancer: 24 2.Empirical for CUP: 18 3. 2nd line: CRC” 16 | 1. 12/24 2. 17% 3. 8/16 | NR | 32 | p=0.0257
CancerTypeID McGee et la, 2011^10^ | 62 | 22 | Squamous cell lung tumors | NR | Squamous cell lung cancer | Lung cancer therapy: 15/20 Head and neck cancer therapy: 2/20 Colorectal cancer therapy: 1/20 Unknown/ missing:2 | | Not applicable: retrospective study | Not applicable: retrospective study
CancerTypeID Thompson, 2011^12^ | NR | NR | NR | NR | Colorectal Cancer | NR | Response: 70% NR | NR | NR | NR
PathworkDx Laouri 2011^31^ | 284 Non-specific dx: 183 Specific Dx: 101 | 284 | NR | SS | TOO Predicted: 221 (78%) Colorectal (15%) Breast (15%) Ovary (13%) Pancreas (13%) Nonsmall Cell Lung (11%) Hepatocellular (11%) Sarcoma, Kidney, Gastric, Other (78%) | Change in first line therapy: Initial Non-specific Primary Site: 135 Major, 37 Minor, 11 None Specific Primary site: 43 Major; 14 Minor; 44 None | NR | 55 (19%) | 229 (81%) | NR
PathworkDx Nystrom 2012^34^ | 316 physicians | 65 physicians 107 patients | Survey | NR | NR | NR | NR | 17 | Any change: 70/107 (65%, 95% CI: 58%–73%) Chemotherapy changed: 58/107 (54%, 95% CI:46%–62%) Radiation therapy: 27/107 (25%) Increase in consistency with guidelines: 23% | NR

Abbreviations: CI = confidence interval; CRC = colorectal cancer; CUP = cancer of unknown primary; ECOG = Eastern Cooperative Oncology Group; NR = not reported; NS = not significant; TOO = tissue of origin.

Table C-8 KQ 4b. Evidence of genetic tissue-of-origin tests changed outcomes

Tissue of Origin Test, Author, Year | # Eligible | # Participated | Cancer/ Tumor Types | Sample Requirements | Score | Indicated TOO | Outcome | Effect of TOO | p-value TOO vs. CUP
CancerTypeID Greco 2012^3^ | 32 CTID: 21 Veridex: 11 | 32 | CUP | As marketed | NR | Colorectal cancer based on CTID or Veridex | Median survival: 2-year survival: 4-year survival: | Total sample: 21 months (95% CI: 17.1–24.9) First-line or second-line CRC treatment: (29 patients) 22 months First-line CRC treatment: 22 months Total sample: 42% Total sample: 35% No Control Group
CancerTypeID Hainsworth, 2012^6^ 2008–2011 | 223 historic controls | Empiric CUP therapy: 29 Site-specific therapy: 194 | CUP | NR | NR | Biliary tract, urothelium, colorectal, lung, pancreas, breast, ovary, gastroesophageal, kidney, liver, sarcoma, cervix, neuroendocrine, prostate, germ cell, skin, intestine, mesothelioma, thyroid, endometrium, melanoma, lymphoma, head and neck, adrenal | Median survival | TOO: 12.5 months (95% CI: 9.1–15.4) Historical control: 9.1 months
CancerType ID Hainsworth, 2011^4^ | 125 | 42 (34%) | CUP or other Identified by TOO as colorectal adenocarcinoma | As marketed | Identified by TOO test with ≥80% probability as colorectal adenocarinoma | Colorectal adenocarinoma | Survival TOO: 8.5 months Control: Empirical CUP 6 months | NR | 0.11
CancerTypeID Thompson, 2011^12^ | NR | NR | CUP with colorectal TOO result | NR | NR | Colorectal cancer | Median survival | 21 months No control group
G-banded karyotype (supplemented by FISH and comparative genomic hybridization Pantou, 2003^15^ | NR | NR | 5/20 identified cases 2/20 no mitoses 1/20 normal karyotype | NR | NR | NR | Median survival | Simple chromosomal changes: 19.7 months Complex changes: 3 months No control group
PathworkDx Hornberger 2012^28^ | 308 treating physicians who ordered TOO test | 65 (21%) | Any | As marketed | NR | NR | Overall survival: projected increase, 15.9–19.5 months Average estimated increase in survival adjusted for QOL: 2.7 months | No control group
PathworkDx Nystrom et al., 2012^34^ | NR | NR | CUP | NR | NR | NR | Survival 14 months 95% CI (10.2–18.6) 2-year survival 33% 3-year survival 30% | CRC (19%) Breast (14%) Sarcoma (14%) Lung (11%) Ovarian (11%) Pancreas (10%)

Abbreviations: CI = confidence interval; CRC = colorectal cancer; CUP = cancer of unknown primary; FISH = fluorescent in situ hybridization; NR = not reported; QOL = quality of life; TOO = tissue of origin.

## References

1 Erlander MG, Ma X-J, Kesty NC, et al. Performance and clinical evaluation of the 92-gene real-time PCR assay for tumor classification. J Mol Diagn. 2011;13(5):493-503. [pmid: 21708287].
2 Greco FA, Spigel DR, Yardley DA, et al. Molecular profiling in unknown primary cancer: accuracy of tissue of origin prediction. Oncologist. 2010;15(5):500-506. [pmid: 20427384].
3 Greco FA. Cancer of unknown primary site: evolving understanding and management of patients. Clin Adv Hematol Oncol. Aug. 2012;10(8):518-524. [pmid: 23073050].
4 Hainsworth JD, Schnabel CA, Erlander MG, et al. A retrospective study of treatment outcomes in patients with carcinoma of unknown primary site and a colorectal cancer molecular profile. Clin Colorectal Cancer. Jun. 2012;11(2):112-118. [pmid: 22000811].
5 Hainsworth JD, Spigel DR, Rubin M, et al. Treatment of carcinoma of unknown primary site (CUP) directed by molecular profiling diagnosis: a prospective, phase II trial. American Society of Clinical Oncology Annual Meeting. 2010. June. Abstract #10540.
6 Hainsworth JD, Rubin MS, Spigel DR, et al. Molecular gene expression profiling to predict the tissue of origin and direct site-specific therapy in patients with carcinoma of unknown primary site: a prospective trial of the Sarah Cannon Research Institute. J Clin Oncol. Jan. 10. 2013;31(2):217-223. [pmid: 23032625].
7 Kerr SE, Schnabel CA, Sullivan PS, et al. Multisite validation study to determine performance characteristics of a 92-gene molecular cancer classifier. Clin Cancer Res. Jul. 15. 2012;18(14):3952-3960. [pmid: 22648269].
8 Kerr SE, Schnabel CA, Sullivan PS, et al. Use of a 92-gene molecular classifier to predict the site of origin for primary and metastatic tumors with neuroendocrine differentiation. Lab Invest. 2012;92:147A.
9 Ma XJ, Patel R, Wang X, et al. Molecular classification of human cancers using a 92-gene real-time quantitative polymerase chain reaction assay. Arch Pathol Lab Med. Apr. 2006;130(4):465-473. [pmid: 16594740].
10 McGee RS, Kesty NC, Erlander MG, et al. Molecular tumor classification using a 92-gene assay in the differential diagnosis of squamous cell lung cancer. Community Oncology. 2011;8(3):123-131.
11 Schroeder BE, Laouri M, Chen E, et al. Pathological diagnoses in cases of indeterminate or unknown primary submitted for molecular tumor profiling. Lab Invest. 2012;92:105A-106A.
12 Thompson DS, Hainsworth JD. Molecular tumor profiling (MTP) in cancer of unknown primary site (CUP): A complement to standard pathologic diagnosis. J Clin Oncol. May. 20. 2011;29(15_suppl: May 20 Supplement):10560. 2011.
13 Weiss L, Chu P. Blinded comparator study of immunohistochemistry (IHC) versus a 92-gene cancer classifier in the diagnosis of primary site in metastatic tumors. J Clin Oncol. 2012;30(15_suppl, May 20 Supplement):e21019.
14 Wu F, Huang D, Wang L, et al. 92-gene molecular profiling in identification of cancer origin: A retrospective study in Chinese population and performance within different subgroups. PLoS One. 2012;7(6).
15 Pantou D, Tsarouha H, Papadopoulou A, et al. Cytogenetic profile of unknown primary tumors: clues for their pathogenesis and clinical management. Neoplasia. Jan-Feb. 2003;5(1):23-31. [pmid: 12659667].
16 Chajut A, et al. Development and validation of a second generation microRNA-based assay for diagnosing tumor tissue origin. AACR. 2011.
17 Meiri E, Mueller WC, Rosenwald S, et al. A second-generation microRNA-based assay for diagnosing tumor tissue origin. Oncologist. 2012;17(6):801-812. [pmid: 22618571].
18 Mueller WC, Spector Y, Edmonston TB, et al. Accurate classification of metastatic brain tumors using a novel microRNA-based test. Oncologist. 2011;16(2):165-174. [pmid: 21273512].
19 Pavlidis N, Pentheroudakis G. Accuracy of microRNA-based classification of metastases of unknown primary. J Clin Oncol. 2012;30. suppl abstr 10575.
20 Rosenfeld N, Aharonov R, Meiri E, et al. MicroRNAs accurately identify cancer tissue origin. Nat Biotechnol. Apr. 2008;26(4):462-469. [pmid: 18362881].
21 Rosenwald S, Gilad S, Benjamin S, et al. Validation of a microRNA-based qRT-PCR test for accurate identification of tumor tissue origin. Mod Pathol. Jun. 2010;23(6):814-823. [pmid: 20348879].
22 Varadhachary GR, Spector Y, Abbruzzese JL, et al. Prospective gene signature study using microRNA to identify the tissue of origin in patients with carcinoma of unknown primary. Clin Cancer Res. Jun. 15. 2011;17(12):4063-4070. [pmid: 21531815].
23 Azueta A, Maiques O, Velasco A, et al. Gene expression microarray-based assay to determine tumor site of origin in a series of metastatic tumors to the ovary and peritoneal carcinomatosis of suspected gynecologic origin. Hum Pathol. 2012. Aug. 30. [pmid: 22939961].
24 Beck AH, Rodriguez-Paris J, Zehnder J, et al. Evaluation of a gene expression microarray-based assay to determine tissue type of origin on a diverse set of 49 malignancies. Am J Surg Pathol. Jul. 2011;35(7):1030-1037. [pmid: 21602661].
25 Dumur CI, Lyons-Weiler M, Sciulli C, et al. Interlaboratory performance of a microarray-based gene expression test to determine tissue of origin in poorly differentiated and undifferentiated cancers. J Mol Diagn. Jan. 2008;10(1):67-77. [pmid: 18083688].
26 Grenert JP, Smith A, Ruan W, et al. Gene expression profiling from formalin-fixed, paraffin-embedded tissue for tumor diagnosis. Clin Chim Acta. Jul. 15. 2011;412(15–16):1462-1464. [pmid: 21497155].
27 Hainsworth J, Pillai R, Henner DW, et al. Molecular tumor profiling in the diagnosis of patients with carcinoma of unknown primary site: retrospective evaluation of gene microarray assay. J Molec Bio and Diagn. 2011. http://www.pathworkdx.com/clinical_information/publications/. Accessed January 15, 2013.
28 Hornberger JD I. Cost effectiveness of gene expression profiling for tumor site origin. AACR IASLC Joint Conference on Molecular Origins of Lung Cancer: Biology, Therapy, and Personalized Medicine; 2012. January 10, 2012. San Diego, CA.
29 Kulkarni A, Pillai R, Ezekiel AM, et al. Comparison of histopathology to gene expression profiling for the diagnosis of metastatic cancer. Diagn Pathol. Aug. 21. 2012;7(1):110. [pmid: 22909314].
30 Lal A, Panos R, Marjanovic M, et al. A gene expression profile test for the differential diagnosis of ovarian versus endometrial cancers. Oncotarget. Feb. 2012;3(2):212-223. [pmid: 22371431].
31 Laouri M, Halks-Miller M, Henner WD, et al. Potential clinical utility of gene-expression profiling in identifying tumors of uncertain origin. Pers Med. 2011;8(6):615-622.
32 Monzon FA, Medeiros F, Lyons-Weiler M, et al. Identification of tissue of origin in carcinoma of unknown primary with a microarray-based gene expression test. Diagn Pathol. 2010;5:3. [pmid: 20205775].
33 Monzon FA, Lyons-Weiler M, Buturovic LJ, et al. Multicenter validation of a 1,550-gene expression profile for identification of tumor tissue of origin. J Clin Oncol. May. 20. 2009;27(15):2503-2508. [pmid: 19332734].
34 Nystrom SJ, Hornberger JC, Varadhachary GR, et al. Clinical utility of gene-expression profiling for tumor-site origin in patients with metastatic or poorly differentiated cancer: impact on diagnosis, treatment, and survival. Oncotarget. Jun. 2012;3(6):620-628. [pmid: 22689213].
35 Pillai R, Deeter R, Rigl CT, et al. Validation and reproducibility of a microarray-based gene expression test for tumor identification in formalin-fixed, paraffin-embedded specimens. J Mol Diagn. Jan. 2011;13(1):48-56. [pmid: 21227394].
36 Pollen M, Wellman G, Lowery-Nordberg M. Utility of gene-expression profiling for reporting difficult-to-diagnose cancers. J Mol Diagn. 2011;13(6):764.
37 Stancel GA, Coffey D, Alvarez K, et al. Identification of tissue of origin in body fluid specimens using a gene expression microarray assay. Cancer Cytopathol. Feb. 25. 2012;120(1):62-70. [pmid: 21717591].
38 Wu AH, Drees JC, Wang H, et al. Gene expression profiles help identify the tissue of origin for metastatic brain cancers. Diagn Pathol. 2010;5:26. [pmid: 20420692].
39 Dumur CI, Fuller CE, Blevins TL, et al. Clinical verification of the performance of the pathwork tissue of origin test: utility and limitations. Am J Clin Pathol. Dec. 2011;136(6):924-933. [pmid: 22095379].
40 Simon R, Radmacher MD, Dobbin K, et al. Pitfalls in the use of DNA microarray data for diagnostic and prognostic classification. J Natl Cancer Inst. Jan. 1. 2003;95(1):14-18. [pmid: 12509396].
41 Laouri M, Nystrom JS, Halks-Miller M, et al. Impact of a gene expression-based tissue of origin test on diagnosis and recommendations for first-line chemotherapy. ASCO. 2010 June 4–8. Chicago, IL.