# Search Strategies

## Search Strategy #1

PubMed
#1 | Search Neoplasms, Unknown Primary[mh] | 2398
#2 | Search (“Gene Expression Profiling”[MeSH]) OR “Microarray Analysis/methods”[Majr] | 64521
#3 | Search #1 AND #2 | 38
#4 | Search Pathwork diagnostics OR Agendia OR CancerTypeID OR MiRview Mets test OR Rosetta Genomics OR AviaraDX OR Quest Diagnostics | 18686
#5 | Search #1 AND #4 | 6
#6 | Search #3 OR #5 | 39
#7 | Search #3 OR #5 Limits: Humans, English, Publication Date from 2000 | 35
#8 | Search Neoplasms/genetics[mh] | 229992
#9 | Search Neoplasms/classification[Majr] OR Neoplasms/diagnosis[Majr] | 607681
#10 | Search #8 AND #9 | 39811
#11 | Search (“Reproducibility of Results”[Mesh]) OR “Sensitivity and Specificity”[Mesh] | 478953
#12 | Search #10 AND #11 | 2966
#13 | Search Oligonucleotide Array Sequence Analysis/methods[Majr] | 8345
#14 | Search #12 AND #13 | 102
#15 | Search #12 AND #13 Limits: Humans, English, Publication Date from 2000 | 96
#16 | Search #10 AND #4 Limits: Humans, English, Publication Date from 2000 | 72
#17 | Search #3 OR #15 OR #16 Limits: Humans, English, Publication Date from 2000 | 195

PubMed = 195 unique citations.

Similar search terms were used for the Cochrane Database = 82 unique citations.

Grey literature databases: EMBASE (was searched specifically for the tests by name). Biosis Previews, Academic Search Premier, Business Source Premier, Health Source, NexisLexis, Academic OneFile, and Scirus) = 15 unique citations.

When all results were combined and duplicates removed, the total database contained 292 records.

## Search Strategy #2

PubMed
#13 | Search ”tissue of origin” and “cancer” | 188
#14 | Search neoplasms, unknown primary | 6765
#15 | Search neoplasms, unknown primary/genetics | 82
#18 | Search #13 OR #15 | 259
#19 | Search #13 OR #15 Limits: Humans, English | 219
#20 | Search #13 OR #15 Limits: Humans, English, Publication Date from 2000 | 157

PubMed = 157 unique citations.

Similar search terms were used for the Cochrane Database = 82 unique citations.

Grey literature databases: EMBASE (was searched specifically for the tests by name). Biosis Previews, Academic Search Premier, Business Source Premier, Health Source, NexisLexis, Academic OneFile, and Scirus) = 108 unique citations.

When all results were combined and duplicates removed, the total database contained 347 records.

The two search strategies were combined yielding 522 unique citations for title and abstract review.

## Search Strategy #3

PubMed

#1Search “tissue of origin” AND “cancer” 201

#2Search Neoplasms, Unknown Primary/Genetics 93

#4Search #1 OR #2 282

#5Search #1 OR #2 Filters: Humans 255

#6Search #1 OR #2 Filters: Humans; English 245

#9Search (“2011/10/01”[Date - Entrez] : “3000”[Date - Entrez]) Field: Date - Entrez Filters: Humans; English 198318

#11Search #6 AND #9 Field: Date - Entrez Filters: Humans; English 13

PubMed = 13 unique citations.

Similar search terms were used for the Cochrane Database = 7 unique citations.

Grey literature databases: EMBASE (was searched specifically for the tests by name). Biosis Previews, Academic Search Premier, Business Source Premier, Health Source, NexisLexis, Academic OneFile, and Scirus) = 45 unique citations.

When all results were combined and duplicates removed, the total database contained 45 records.

## Search Strategy #4

PubMed

#1 Search (Neoplasms, Unknown Primary[mh]) AND ((“Gene Expression Profiling”[MeSH]) OR “Microarray Analysis/methods”[Majr]) Filters: Humans; English 47

#2 Search (Neoplasms, Unknown Primary[mh]) AND ((“Gene Expression Profiling”[MeSH]) OR “Microarray Analysis/methods”[Majr]) Filters: English 47

#3 Search (Neoplasms, Unknown Primary[mh]) AND (Pathwork diagnostics OR Agendia OR CancerTypeID OR MiRview Mets test OR Rosetta Genomics OR AviaraDX OR Quest Diagnostics) Filters: English 8

#4 Search (#2 OR #3) Filters: English 47

#5 Search (#2 OR #3) Filters: Publication date from 2012/08/01 to 2012/11/07; English 0

#6 Search (#2 OR #3) Schema: all Filters: Publication date from 2012/08/01 to 2012/11/07; English 0

#7 Search (Neoplasms/genetics[mh]) AND (Neoplasms/classification[Majr] OR Neoplasms/diagnosis[Majr]) Filters: English 43921

#8 Search (“Reproducibility of Results”[Mesh]) OR “Sensitivity and Specificity”[Mesh] Filters: English 521700

#9 Search Oligonucleotide Array Sequence Analysis/methods[Majr] Filters: English 9024

#10 Search (#7 and #8 and #9) Filters: English 104

#11 Search (#7 and #8 and #9) Schema: all Filters: Not Human, English 4

#12 Search ((“tissue of origin” AND “cancer”)) AND Neoplasms, Unknown Primary/Genetics Filters: Publication date from 2012/08/01 to 2012/11/07; English 0

#13 Search ((“tissue of origin” AND “cancer”)) AND Neoplasms, Unknown Primary/Genetics Schema: all Filters: Publication date from 2012/08/01 to 2012/11/07; English 0

#15 Search ((“tissue of origin” AND “cancer”)) or Neoplasms, Unknown Primary/Genetics Filters: English 284

#17 Search ((“tissue of origin” AND “cancer”)) or Neoplasms, Unknown Primary/Genetics Filters: Publication date from 2012/08/01 to 2012/11/07; English 9

#18 Search ((“tissue of origin” AND “cancer”)) or Neoplasms, Unknown Primary/Genetics Filters: Humans; English 251

#19 Search (#15 NOT #18) 33

PubMed = 36 unique citations.

Similar search terms were used for the Cochrane Database = 8 unique citations.

Grey literature databases: Biosis Previews, Academic Search Premier, Business Source Premier, Health Source, NexisLexis, Academic OneFile, and Scirus) = 24 unique citations.

When all results were combined and duplicates removed, the total database contained 65 records.