# Inclusion and Exclusion Criteria

## Inclusion Criteria

- TEST TYPE: Genetic or molecular test used for the identification tumor tissue-of-origin that are commercially available (one for which an internet search or test directory identified a mechanism for a physician or laboratory to order the test or to buy a kit to perform the test) in the United States.
- STUDY TYPE: Systematic reviews randomized controlled trials, nonrandomized controlled trials, prospective and retrospective cohort studies, case-control studies, and case series published from 1990 to present that were relevant to at least one of the key questions. Conference presentations and posters from 1990 to present with presented data not published elsewhere.

## Exclusion Criteria

- Non-English studies