# Executive Summary

## Introduction

The purpose of this technology assessment is to assess the evidence on the analytical validity, clinical validity, and clinical utility of commercially available genetic tests for identifying the tissue of origin (TOO) of the cancer in patients with cancer of unknown primary (CUP) site. This report was requested by the Centers for Medicare & Medicaid Services and was conducted through the Evidence-based Practice Center (EPC) Program at the Agency for Healthcare Research and Quality (AHRQ).

## Methods

The review focused on five key questions (KQs) identified in the protocol, assessed the quality of evidence for each question, and synthesized the results across studies for the same test using a meta-analytic approach when there was sufficient information across the studies. The KQs were as follows:

1. What genetic or molecular TOO tests are available for clinical use in the United States and what are their characteristics?
2. What is the evidence on the analytic validity of the TOO tests?
3. What is the evidence regarding the accuracy of genetic TOO tests in classifying the origin and type of CUP?
  a. Does it differ by tumor origin?
  b. Does it differ by patient age, sex, race, or ethnicity?
4. What is the evidence that genetic TOO tests change treatment decisions and improve clinical outcomes?
5. Is the evidence regarding genetic TOO tests relevant to the Medicare population?

## Approach to Evaluating the Literature

The scope of the review was limited to tests that are commercially available in the United States. We identified genetic or molecular TOO tests by searching GeneTests.org, the NIH Genetic Testing Registry, the GAPP Knowledge Base, and the following Food and Drug Administration databases: Premarket Notifications (510(k)), Premarket Approvals, and Clinical Laboratory Improvement Amendments. We also searched the Internet for tests to identify TOO in patients with CUP. We defined a “commercially available” test as one for which an Internet search or test directory identified a mechanism for a physician or laboratory to order the test or to buy a kit to perform the test.

We included systematic reviews, randomized controlled trials, nonrandomized controlled trials, prospective and retrospective cohort studies, case-control studies, and case series published from 1990 to present. We excluded non-English studies; a preliminary search found very few studies published in other languages. We searched the grey literature for relevant studies but did not contact authors for additional data. We included conference presentations and posters when they presented data not published elsewhere.

## Quality Assessment

We assessed the risk of bias in the reviewed studies using the criteria described in the Methods Guide for Medical Test Reviews.1 For studies of analytic or clinical validity (KQs 2 and 3), we used the QUADAS2 to assess the potential for bias due to flaws in the sample selection, testing protocol, reference standards, verification procedures, interpretation, and analysis. We used Simon3 criteria to assess the validity of the development of statistical classification algorithms. For studies of clinical utility (KQ 4), we used questions from the RTI International Question Bank4 to assess the potential for bias from sample selection, study performance, attrition, detection of outcomes, and reporting. Quality assessment results were summarized as good, fair, or poor, correlating with a low, medium, or high risk of bias.

## Data Synthesis

We summarized the evidence for each KQ in the evidence tables. For each of the three genomic tests, two or more studies assessed the ability of the test to correctly identify tumors of known origin. Given the consistency of the accuracy rates across the studies and overlapping confidence intervals, we did a meta-analysis using a fixed effects model to estimate a summary measure of accuracy.

Although more than three studies assessed the accuracy of the test in identifying the site of the primary tumor for true CUP cases for all three tests, the standards used to judge the accuracy of the TOO call varied among studies, and the validity of some standards were questionable. Therefore, we did not include a summary measure of accuracy across these studies.

## Grading the Evidence for Each Key Question

We graded the overall strength of evidence according to the guidance established for the EPC Program.1, 5 This approach incorporated four key domains: risk of bias (including study design and aggregate quality), consistency, directness, and precision of the evidence. Grades reflect the strength of the body of evidence to answer the KQs on the validity and efficacy of the interventions in this review. Two senior reviewers assessed each domain and the overall grade for each key outcome listed in the framework. Conflicts were resolved by discussing until consensus was reached. For KQs 2 and 3, the strength of evidence was graded for each test. For KQ 3a, we graded the evidence that the statistical algorithm was valid using the Simon3 criteria for the development of statistical classification algorithms. For KQ 4, the strength of evidence was graded for each outcome (e.g., treatment change, clinical outcomes).

## Results

We reviewed four tests—cytogenetic analysis and three molecular tests (CancerTypeID, miRview mets, and PathworkDx)—for analytical validity, clinical validity, and clinical utility (Table A). The published evidence in each of these areas is variable.

Table A Genetic and molecular tests to identify tumor tissue of origin

| Pathworks TOO | CancerTYPEID | Mirview mets | Chromosomal Analysis
Analyte | mRNA | mRNA | microRNA | Chromosomes
Panel size | TOO-FFPE: 1,550 TOO-FRX: 2,000 Endometrial: 316 | 92 | Mets: 48 Mets^2^: 62 | 46
Laboratory methods | Expression microarray analysis | Quantitative real time PCR | Quantitative real time PCR | High resolution G-banded
Statistical methods | Pairwise comparison, machine learning algorithm | Kohonen neural network (KNN) | Binary decision tree and KNN | NA
No. sites identified | FFPE and FRZ: 15 Endometrial: 2 | 28 | Mets: 22 Mets^2^: 24 | NA
Reported results | Similarity score | Probability of each type | Predicted tumor type from each algorithm | Karyotype

Some data on analytic performance were available for all of the three molecular TOO tests, but only the PathworkDx test had sufficient evidence to assess its analytic validity (Table B). The evidence that PathworkDx was analytically valid was high.

Table B Analytic validity

| Pathworks TOO | CancerTYPEID | miRview
Number of studies | 4 | 1 | 5
Total tumors | 640 | 487 | 1,546
Marker accuracy | Coefficient of reproducibility: 32.48+/−3.97 | Reproducibility (Ct values): + controls: 1.7% − controls: 1.3% | Interlaboratory concordance: >0.95%

Two out of three tests have sufficient information included in publications to allow one to assess the validity of the statistical algorithms used in the TOO. The manuscripts describing the PathworkDx TOO test do not have the same degree of detail, so it is difficult to assess the validity of the algorithm with the same degree of confidence (Table C).

Table C Statistical validity of algorithm development

| Pathworks TOO | CancerTYPEID | miRview
Normalization | Total expression | Housekeeping genes | Total expression
Dimension reduction | Not enough detail to assess | Clustering with GLM to assess predictive value | Logistic regression to assess predictive value
Classification rule supervision | Supervised Not enough detail to assess | Supervised | Supervised
Internal validation | Yes | Yes | Yes
External validation | Yes | Yes | Yes
Criteria met? | Mostly – classification and dimension reduction not evaluable | Yes | Yes

At least three studies for each test reported on the ability of the test to identify the primary site for tissues of known origin (Table D). The accuracy rates across all of the studies for each of the three tests are fairly consistent. The summarized accuracy rate for CancerTypeID was 0.85 with 95% confidence interval (CI) (0.83 to 0.86), for miRview mets it was 0.85 with 95% CI (0.83 to 0.87), and for PathworkDx it was 0.88 with 95% CI (0.86 to 0.89).

Table D Clinical validity

| Pathworks TOO | CancerTYPEID | miRview
Number of studies | 9 | 6 | 4
Total tumors | 1,243 | 1,478 | 1,198
Comparison standards | Cancers of known origin/IHC | Final diagnosis | Known origin
Percent accuracy (range) | 74–97 | 82–95 | 85–88
Percent indeterminate (range) | 5–18 | NR | NR
Meta-analysis estimate of accuracy | 0.88 95% CI, 86 to 89% | 0.85 95% CI, 83 to 86% | 0.85 95% CI, 83 to 87%

The ability of the tests to detect CUP cases is not as yet easily determined. The primary tumor site in CUP cases is often never identified. Therefore, only a few reports of test performance in CUP cases have independent confirmation of TOO. Fifteen studies, all rated fair, looked at the clinical utility of the TOO tests. Tables E to G demonstrate the findings in regard to clinical utility in regard to diagnosis, treatment decisions and improving outcomes respectively.

Table E Clinical utility-diagnosis

Outcome | Number of Styles | Summary of Results
TOO predicted | 17 | 57–100% >90% in 9 studies
TOO confirmed | 9 | 48–88%
Test changed or resolved diagnosis | 5 | 44–81%
Test reported to be clinically useful | 1 | 66–67%

Methods of confirmation: Identification of primary site after test, clinicopathological features at test or at end of follow-up.

Table F Clinical utility for treatment decisions

Outcome | Number of Studies | Summary of Results
Treatment changed | 4 | 26% – 81%
Increase in site specific treatment | 1 | 23% increase
Difference in treatment response | 4 | TOO-based: 41–74% Empiric: 17%

Table G Clinical utility for improving outcomes

Outcome | Number of Studies | Summary of Results
Survival (months) TOO-based treatment vs. empiric treatment | 2 | 2.5 – 3.4 month increase
Survival (months) total sample | 3 | 12.9 – 21
Projected increase in survival (months) | 1 | 3.6 months
Projected increased adjusted for quality of life | 1 | 2.7 months
Stable disease | 1 | 32%

We also examined the applicability of the evidence on these tests to the Medicare population. As showin in Table H, the majority of the studies included patients 65 years and older, the core Medicare population, and included patients of both sexes.

Table H Applicability to Medicare patients

Characteristic | Number
Studies of clinical utility | 19
Total patients | 2,398
Studies with patients 65 or older | 13
Both sexes | 14

Given the lack of a gold standard in some reports, we judged the strength of the evidence as moderate that the tests accurately detect the TOO. The strength of evidence was also low that TOO tests affect treatment decisions and length of survival. The evidence was insufficient to answer KQs on the effect of the tests on outcomes.

## Summary of Findings

We assessed four tests in this review: cytogenetic analysis, CancerTypeID, miRview mets, and PathworkDx. Of the three molecular tests, CancerTypeID has the broadest panel with the ability to detect 28 different tumor types; miRview mets has 24 tumor sites on its panel and PathworkDx has 15 tumor sites in its panel. Cytogenetic analysis can only detect a TOO associated with a specific cytogenetic abnormality. Table I summarizes our findings.

The literature on molecular genetic tests for CUP is in its infancy. The published manuscripts that we reviewed suggest that the tests have a high accuracy rate when the TOO is known or in studies where there is a well-defined, valid measure of accuracy. The literature available on the use of these tests in the diagnosis of actual CUP cases is very limited because of the lack of a consensus measure on determining the accuracy of the test’s call. Given the nature of CUP, a standard for identifying the accuracy of the TOO test may not be available in many cases.

In the absence of a good measure of accuracy of the test call, a proxy measure of the utility of the test is its effect on treatment decisions and patient outcomes. The literature on the effect of the test on treatment decisions is very limited. There is low evidence that the test alters the treatment course from empiric therapy usually used in CUP to tissue-specific therapy. The effect of this change in therapy on outcomes is limited to four papers that used CancerTypeID as the TOO test and two on PathworkDx. All but one of the studies used historical controls to determine benefit of therapy. The one study.6 that compared survival between site specific and empiric therapy had a sample size of less than 100 and was focused on CRC. Thus there is no study with a sufficient sample size that compared outcomes between patients who received tissue-specific therapy and those who did not.

One of the concerns is that all but one of the manuscripts reviewed were funded wholly or partly by the manufacturers of the tests. It is not possible at this time to rule out a possibility of publication bias in the available literature.

Table I Overview of study outcomes

Key Question | Number of Studies | Conclusion | Strength of Evidence
KQ 2. Analytic validity: CancerTypeID | 1 | Only one study that was conducted by manufacturer of test. Limited measures of analytic validity reported and impossible to assess consistency of those measures across studies. | Insufficient
KQ 2. Analytic validity: miRview miRview mets | 4 | Four studies each reported different measures of analytic validity. Impossible to evaluate consistency of reported measures of analytical validity across studies. | Insufficient
KQ 2. Analytic validity: PathworkDx | 3 | Three papers reported measures of analytic validity. There is moderate consistency between studies of interlaboratory reproducability. The reported precision in these three papers is high. | High
KQ 2. Analytic validity: PathworkDx Endometrial | 1 | One study reported on the analytic validity of a PathworkDx Endometrial test. The reported precision of the test is high, but there is insufficient evidence to assess analytic validity. | Insufficient
KQ 3a. Adherence to Simon guidelines: CancerTypeID | 2 | Report on the development of the algorithm has sufficient detail on development and validation to assess the validity of the process. Development met the Simon3 criteria. | High
KQ 3a. Adherence to Simon guidelines: miRview mets | 2 | Report on development of algorithm has sufficient detail on development and validation to assess the validity of the process. Development met the Simon3 criteria. | High
KQ 3a. Adherence to Simon guidelines: PathworkDx | 2 | Report on development of algorithm does not have sufficient detail on development and validation to assess the validity of the process. | Low
KQ 3a. Adherence to Simon guidelines: PathworkDX Endometrial | 1 | Report on development of algorithm does not have sufficient detail on development and validation to assess the validity of the process. | Low
KQ 3b. Accuracy of the TOO test in classifying the origin and type of tumors of known primary site: CancerTypeID | 7 | Seven studies representing 1,476 tissue samples compared the ability of tests to identify origin of tumor in tissues of known origin. All report accuracy of inclusion. Accuracy of exclusion reported in two studies. | High
KQ 3b. Accuracy of the TOO test in classifying the origin and type of tumors of known primary site: miRview mets | 4 | Two independent studies representing 898 tissue samples tested the ability of the miRview to identify site of origin in tissues of known origin. Accuracies of inclusion and exclusion are reported for both. | High
KQ 3b. Accuracy of the TOO test in classifying the origin and type of tumors of known primary site: PathworkDx | 9 | Nine studies representing 1,247 tissue samples report on the ability of the test to identify the origin of tumor in tissues of known origin. Accuracy of included tissue is reported in all studies. Accuracy of excluded tissues reported in two studies. | High
KQ 4. Percentage of cases for which a TOO test identified a TOO | 17 | Fifteen studies rated fair provided evidence on this question. The ability of the test to identify a TOO was judged using different criteria in different studies. | Moderate
KQ 4. Percentage of CUP cases for which the TOO identified by the test was independently confirmed | 6 | Five studies all rated fair provided evidence for this question. Gold standard varied across studies and precision across studies was moderate. Accuracy ranged from 57% to 100%. | Low
KQ 4: Percentage of CUP cases where TOO modified diagnosis | 6 | Four studies rated fair and one poster rated good provided evidence for this question. Some explored potential changes; others actual changes. The reported percentage of changes ranged from 65% to 81%. Response rates in the survey were fairly low. | Low
KQ 4: Percentage of CUP cases where test was considered clinically useful by physician or researcher | 6 | All studies found test clinically useful in a proportion of cases. Clinical usefulness was measured differently in each study. Wide estimate in the proportion of cases where test was useful. | Low
KQ 4: Change in treatment decisions | 5 | Studies have small samples, varied study designs and measures of effect on treatment decisions, making it difficult to draw conclusions on any of the tests. | Insufficient
KQ 4: Treatment response: Tissue-specific treatment based on TOO test compared with usual treatment for CUP cases | 4 | Small samples, insufficient studies to draw conclusions on any of the tests. Only one study has a control; all others use historical controls. | Insufficient
KQ 4: Change in survival | 5 | Small samples, insufficient studies to draw conclusions on any of the tests. Most use historical controls. | Low
KQ 4: Change in disease progression | 1 | Small samples, insufficient studies to draw conclusions on any of the tests. | Insufficient
KQ 5: Applicability | 22 | Almost all studies included patients age 65 and older and both male and female patients. The studies that reported race included mostly Caucasian patients. | High

## Future Research

The most urgent need in the literature is to have the tests be evaluated by research groups that have no evident conflict of interest.

Given the difficulty in identifying a valid measure of accuracy of the test in true CUP cases, it seems the most fruitful research would focus on the benefits from the test to the patient in terms of effect on treatment decisions and resulting outcomes.

## References

1 Methods Guide for Medical Test Reviews. Agency for Healthcare Research and Quality. 2010. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=454.
2 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. [pmid: 14606960].
3 Simon R, Radmacher MD, Dobbin K, et al. Pitfalls in the use of DNA microarray data for diagnostic and prognostic classification. J Natl Cancer Inst. Jan. 1. 2003;95(1):14-18. [pmid: 12509396].
4 Viswanathan M, Berkman ND. Development of the RTI Item Bank on Risk of Bias and Precision of Observational Studies. Rockville (MD). 2011.
5 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
6 Hainsworth JD, Schnabel CA, Erlander MG, et al. A Retrospective Study of Treatment Outcomes in Patients with Carcinoma of Unknown Primary Site and a Colorectal Cancer Molecular Profile. Clin Colorectal Cancer. 2011. Oct. 13. [pmid: 22000811].