# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Andra Frost, M.D. , Mansoor Saleh, M.D., Grier Page, Ph.D., and B. Lynn Whitener, Ph.D.,

## Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Harry Burke
  George Washington University
- William Dave Dotson
  CDC-Office of Public Health Genomics
- Lakshman Ramamurthy
  FDA